# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1. DERIVATION OF PROVISIONAL REFERENCE DOSES

The human and animal toxicity literature for dietary P and Na/K salts of inorganic phosphates, coupled with mechanistic information, clearly indicates that impaired P homeostasis is associated with renal toxicity (acute phosphate nephropathy/nephrocalcinosis) and GI symptoms, is potentially associated with cardiovascular effects (including increased risk of mortality or cardiovascular events), and may alter bone composition.

As discussed earlier, oral data pertinent to the hazard assessment of sodium or potassium salts of inorganic phosphates can be grouped into four main categories: human epidemiological studies on associations between dietary P intake and health outcomes; controlled trials of humans exposed to sodium or potassium salts of inorganic phosphates for acute or short-term durations; human studies of renal toxicity or GI symptoms after acute exposure to OSP for bowel cleansing or constipation treatment; and short-term and subchronic animal toxicity studies. Sections 2.1 and 2.2 above provide the rationales for selecting human and animal data for consideration in the assessment, and these details will not be reiterated here.

All the above sources were considered relevant to hazard assessment. However, several of these sources suffer from limitations that render them less useful for dose-response assessment. Specifically, the human dietary intake studies have uncertainties that preclude their use for dose-response assessment. These include potential underestimation of dose estimates and varying bioavailabilities of different P sources. In addition, although the acute colonoscopy preparation studies provide important hazard information and identify clear effect levels, the considerable uncertainty involved in extrapolating from a single-day exposure to subchronic or chronic exposure limits value of these data for dose-response assessment.

Dietary intake of phosphates is difficult to quantify. EFSA (2015) noted that food product processing and formulations change continuously, making it difficult for food composition databases to keep pace with the changes. Further, P-containing food additives are used in a large variety of foods including baked goods, meats, and beverages. To capture the inputs from all of these sources for an epidemiological study requires that the FFQ include all of these foods and be updated over time to reflect changing content. Whether an FFQ administered twice in 4 years correlates with long-term dietary intake patterns is uncertain. Several reviews (McClure et al., 2017; EFSA, 2015) have suggested that dietary intake of P is usually underestimated for the reasons outlined above.

The bioavailability of P from different sources varies widely, as discussed in Section 2.3.3. Oral bioavailability of dietary P depends on the food source (animal or plant derived) and the organic or inorganic form of the P-containing food: bioavailability is lowest for plant sources (10–30%), higher for animal sources (40–60%), and highest for food additives (80–100%), which includes phosphoric acid and several (Na/K) phosphates. Most of the dietary intake studies did not account for different sources of P in the diet, and none of the studies provided estimates of intake for subcategories of dietary P that may be relevant to the assessment of sodium or potassium salts of inorganic phosphates.

As a result of the uncertainties in doses and differing bioavailability of P forms inherent in the dietary intake studies, the studies considered for dose-response assessment for sodium or potassium salts of inorganic phosphates were restricted to those in which a clearly defined test material was administered. These include the controlled human exposure studies, the human colonoscopy preparation studies, and most (but not all) of the animal studies.

A few short-term, controlled-exposure human studies measuring adverse outcomes (Chang et al., 2017; Medoff et al., 2004; Grimm et al., 2001) were identified. These studies ranged in duration from 3 to 6 weeks. Of the three studies, two (Medoff et al., 2004; Grimm et al., 2001) reported that the test material administered to the volunteers, while Chang et al. (2017) reported only that the supplemented P was in the form of food additives provided as commercially available beverages and breakfast bars. Grimm et al. (2001) administered a combination of calcium phosphate (Ca_5_[PO_4_]_3_OH) in orange juice and NaH_2_PO_4_ tablets. Because the supplemental Ca provided by the calcium phosphate may limit the absorption of phosphate, this study also has limitations for dose-response assessment. Finally, Medoff et al. (2004) administered NaH_2_PO_4_ tablets to a group of patients with chronic constipation, but allowed the patients to vary the dose to improve their response or mitigate side effects. Assigning a clear LOAEL for this study is difficult. For these reasons, the controlled exposure studies are not considered to provide reliable dose-response information and are not considered for use in the derivation.

The human colonoscopy preparation studies appear to offer several advantages. First, the test material (sodium phosphate) is clearly defined, consistent across exposed persons, and of predictable bioavailability. In addition, unlike the dose estimates in dietary intake studies, the prescribed dose of sodium phosphate taken in preparation for colonoscopy is well characterized. The primary disadvantage of the human colonoscopy preparation studies for dose-response assessment is that exposure to inorganic phosphates occurred for only a single day; thus, using these data to derive a provisional reference dose (p-RfD) would necessitate extrapolation from a single-day exposure to subchronic or chronic exposure. Some evidence suggests that intake-related, short-term spikes in serum P may lead to acute insults (e.g., transient decreases in endothelial dysfunction) (Nishi et al., 2015; Shuto et al., 2009) that could accumulate over time and lead to permanent damage or functional changes, despite homeostatic mechanisms that regulate serum P. However, due to the uncertainty in extrapolating from effects of a single day to subchronic or chronic exposure, these data were not selected for use in p-RfD derivation.

Given the limitations articulated above in the human toxicity database, these studies were not used for toxicity value derivation, which instead relies on animal toxicity data. The human toxicity information is used as supporting information: specifically, the estimated effect levels defined by the colonoscopy preparation studies, FDA warnings, and controlled exposure studies were compared with the p-RfDs derived from the animal studies to ensure that the p-RfDs will adequately protect against effects observed in humans exposed for acute and short-term durations.

### 3.1.1. Derivation of the Subchronic Provisional Reference Dose

The published, peer-reviewed rabbit study by Ritskes-Hoitinga et al. (2004) was selected as the principal study for deriving the subchronic p-RfD for Na/K salts of inorganic phosphates.

Several subchronic animal studies met criteria for inclusion in the assessment (see Table 3A). Among these studies, the lowest LOAEL was 290 mg P/kg-day (HED 120 mg/kg-day) for nephrocalcinosis in rabbits (Ritskes-Hoitinga et al., 2004). LOAELs in the other studies in the database were as high as 1,100 mg P/kg-day (HED 270 mg/kg-day) based on renal, bone, and body-weight effects in rats (Abuduli et al., 2016; Huttunen et al., 2007; Tani et al., 2007; Koshihara et al., 2005; Ritskes-Hoitinga et al., 1989; Hitchman et al., 1979; Datta et al., 1962; Dymsza et al., 1959). One of the two subchronic experiments reported by Datta et al. (1962) lacked information needed to identify a LOAEL, so this experiment was not considered. From the remaining experiments, the five identifying the lowest LOAELs were considered for use in the dose-response assessment: Huttunen et al. (2007), Koshihara et al. (2005), Ritskes-Hoitinga et al. (2004), Ritskes-Hoitinga et al. (1989), and the remaining experiment reported by Datta et al. (1962).

All these studies were limited in examination of toxicological endpoints, mostly focusing on renal, cardiovascular, or bone effects. Candidate points of departure (PODs) from these studies, reported in HEDs (see calculations in study descriptions in Sections 2 and 2.2), are shown in Table 16. As discussed above and shown in the table, all the animal studies included a referent (“control”) group with nonzero phosphate intake, because P is an essential nutrient, and a lack of P in the diet is harmful to health. The doses administered to the referent groups are reported in the table but should not be interpreted as NOAELs (due to the lack of a comparison group) and were not considered as candidate PODs.

Table 16 Candidate PODs for Noncancer Dose-Response Assessment of Na/K Salts of Inorganic Phosphates

Species and Study Type | Endpoint | LOAEL (HED) (mg P/kg-d) | Referent Group Dose (HED) (mg P/kg-d) | Reference
Rabbit; dietary exposure to NaH_2_PO_4_ dihydrate for 8 wk | Nephrocalcinosis, on the basis of significantly increased kidney Ca and P, and significantly increased incidence and severity scores for cortical calcifications | 120 | 63 | Ritskes-Hoitinga et al. (2004)
Rat; dietary exposure to NaH_2_PO_4_ dihydrate for 4 wk | Nephrocalcinosis, on the basis of statistically or biologically significant increases in urine albumin and relative kidney weights | 120 | 86 | Ritskes-Hoitinga et al. (1989)
Rat; dietary exposure to KH_2_PO_4_ for 6 wk | Significantly bmd (fifth lumbar vertebra), significantly increased serum osteocalcin and urinary deoxypyridinoline | 200 | 68 | Koshihara et al. (2005)
Rat; dietary exposure to Na_2_HPO_4_ for 16 wk | Increased relative kidney weight (17–39%); impaired kidney function; increased incidence of renal histopathology (medullary calcification and necrosis, tubular casts, hemorrhages/exudate, chronic inflammatory changes) | 200 | 67 | Datta et al. (1962)
Rat; dietary exposure to CaHPO_4_ and KH_2_PO_4_ for 8 wk | Significantly decreased body weight (11%) and food intake; significantly decreased bmc and bmd; alterations in several measures of bone histomorphometry; nonsignificant decrease in bone strength. | 240 | 120 | Huttunen et al. (2007)

bmc = bone mineral content; bmd = bone mineral density; Ca = calcium; CaHPO_4_ = calcium phosphate; HED = human equivalent dose; KH_2_PO_4_ = monopotassium phosphate; LOAEL = lowest-observed-adverse-effect level; Na/K = sodium and potassium; Na_2_HPO_4_ = disodium phosphate; NaH_2_PO_4_ = monosodium phosphate; P = phosphorus; POD = point of departure.

The lowest LOAELs (HED) (120 mg P/kg-day) are based on nephrocalcinosis in male rabbits exposed to NaH_2_PO_4_ in the diet for 8 weeks (Ritskes-Hoitinga et al., 2004) and also in female rats exposed to NaH_2_PO_4_ in the diet for 4 weeks (Ritskes-Hoitinga et al., 1989). Renal effects were also the basis of the LOAEL (HED) (200 mg P/kg-day) for the subchronic study (Datta et al., 1962), in which rats received Na_2_HPO_4_ for 16 weeks. The renal effects seen in these studies (nephrocalcinosis, increased kidney weights, impaired kidney function) are similar to the acute and chronic kidney injury (e.g., acute phosphate nephropathy) seen in some human studies after exposure to OSP compounds for colonoscopy preparation. The fact that this potential POD is identical in rats and rabbits adds confidence for nephrocalcinosis as the critical effect and 120 mg/kg-d P as the POD.

LOAEL (HED) values for the other two studies shown in Table 16 (Huttunen et al., 2007; Koshihara et al., 2005) were 240 and 200 mg P/kg-day (respectively) based on decreases in bmd and related parameters. Unlike for renal effects, there is less evidence for parallel changes in bone metabolism in humans exposed to higher dietary intakes of phosphates, although the available literature examining these endpoints suffers from the same limitations as other dietary intake studies. Available information in humans appears to point to improved bone health with higher dietary P intake (Jones et al., (http://heronet.epa.gov/heronet/index.cfm/reference/details/reference_id/4854793) as cited in EFSA, 2015; Heppe et al., 2013; Yin et al., 2010; Tobias et al., 2005; Elmståhl et al., 1998). Because the bone effects in animals are not clearly reflected in effects seen in humans while renal effects are, and given the lower LOAELs for renal effects, neither Koshihara et al. (2005) nor Huttunen et al. (2007) was considered further for use in the derivation.

Ritskes-Hoitinga et al. (2004), Ritskes-Hoitinga et al. (1989), and Datta et al. (1962) did not include more than one nonreferent dose with suitable data, so these data sets were not amenable to benchmark dose (BMD) modeling. Both Ritskes-Hoitinga et al. (2004) and Ritskes-Hoitinga et al. (1989) identified a LOAEL (HED) value of 120 mg P/kg-day, which is lower than the LOAEL (HED) value from Datta et al. (1962). Thus, these studies were selected for use in deriving the subchronic p-RfD for Na/K salts of inorganic phosphates, and the LOAEL (HED) of 120 mg P/kg-day for increased incidence of nephrocalcinosis in rabbits exposed to NaH_2_PO_4_ dihydrate for 8 weeks via the diet (Ritskes-Hoitinga et al., 2004) was selected as the POD for derivation of the subchronic p-RfD.

The subchronic p-RfD for extra-dietary exposure to Na/K salts of inorganic phosphates is derived by applying a composite uncertainty factor (UF_C_) of 30 (reflecting an interspecies uncertainty factor [UF_A_] of 3, an intraspecies uncertainty factor [UF_H_] of 3, and a LOAEL-to-NOAEL uncertainty factor [UF_L_] of 3) to the selected POD (HED) of 120 mg P/kg-day.

Subchronic p-RfD = POD ( HED ) ÷ UF_C_ = 120 mg P/kg-day ÷ 30 = 4 mg P/kg-day as sodium or potassium salts of inorganic phosphates

Table 17 summarizes the uncertainty factors for the subchronic p-RfD for Na/K salts of inorganic phosphates. Uncertainty factors were applied in accordance with applicable guidance and methodology (U.S. EPA, 2011b, 2002).

Table 17 Uncertainty Factors for the Subchronic p-RfD for Na/K Salts of Inorganic Phosphates

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rats and humans following Na/K phosphate exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b).
UF_D_ | 1 | A UF_D_ of 1 is applied in accordance with U.S. EPA (2002), because reproductive and developmental toxicity studies in rats, rabbits, mice, and hamsters are available (see Table 11) and show no indication of effects at doses below those in subchronic and chronic studies. Additionally, numerous short-term, subchronic, and chronic oral studies in several species are available that investigated a variety of health effects. The evidence base also comprises numerous epidemiological studies including controlled exposure studies, cohort and case-control dietary intake studies, and randomized studies of OSP use for bowel preparation or constipation that report health effects.
UF_H_ | 3 | A UF_H_ of 3 (10^0.5^) is applied to account for low human variability in susceptibility to P, due to tightly regulated homeostatic mechanisms in average individuals. Populations with pre-existing kidney disease may be more susceptible. CKD is known to increase susceptibility to inorganic phosphate toxicity, and its prevalence in the United States is around 14% (NIDDK, 2016). However, the differences in susceptibility are modest and are captured in the available human data. For instance, the prospective study by Yoon et al. (2017) found no effect of increased P intake on incidence of CKD in nondiabetic adults followed for 8 yr but did see an increased incidence in CKD in the highest P exposed quartile of diabetics. Support for using a UF_H_ of 3 is provided by the fact that the p-RfD based on Ritskes-Hoitinga et al. (2004) is more protective than a p-RfD derived based on kidney effects observed in the susceptible (diabetic) population in Yoon et al. (2017) .
UF_L_ | 3 | A UF_L_ of 3 (10^0.5^) is applied because the POD is a LOAEL. The difference between LOAEL and referent group dose in the study was ~twofold, and the incidence of nephrocalcinosis in the referent group was not significantly different than the next lower dose (indicating the referent group approximates a NOAEL). Therefore, a full 10-fold uncertainty factor is not considered appropriate.
UF_S_ | 1 | A UF_S_ of 1 is applied because the subchronic POD is from a subchronic (8-wk) study.
UF_C_ | 30 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

CKD = chronic kidney disease; DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; Na/K = sodium and potassium; NOAEL = no-observed-adverse-effect level; OSP = oral sodium phosphate; P = phosphorus; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor; U.S. EPA = U.S. Environmental Protection Agency.

Confidence in the subchronic p-RfD for Na/K salts of inorganic phosphates is medium, as described in Table 18.

Table 18 Confidence Descriptors for the Subchronic p-RfD for Na/K Salts of Inorganic Phosphates

Confidence Categories | Designation | Discussion
Confidence in study | M | Confidence in the principal study is medium. Ritskes-Hoitinga et al. (2004) exposed small groups (eight per dose) of male rabbits for 8 wk to diets containing four different P concentrations, but only two contained at least the minimum level of P (0.4%) recommended for rabbits (Clarke et al., 1977). However, the study used a well-characterized diet and controlled for dietary Ca. In addition, the renal endpoint (nephrocalcinosis) and POD are supported by a similar study in rats (Ritskes-Hoitinga et al., 1989). Endpoints tested in these studies, although limited compared with a comprehensive subchronic toxicity study, included sensitive endpoints known or believed to be associated with phosphate intake. Endpoints included body weight/growth and feed intake, urine and fecal mineral content, weight and histology of the kidney, and femur dimensions and mineral content.
Confidence in database | M | Confidence in the database is medium. The database comprises numerous epidemiological studies including controlled exposure studies, cohort and case-control dietary intake studies, and randomized studies of OSP use for bowel preparation or constipation that report a variety of health effects. Although the database includes many human studies, these suffer from several limitations, including uncertainty in doses and relevance of dietary P (i.e., organic and inorganic sources of P). The database also contains short-term, subchronic, and chronic oral studies in rats, rabbits, and dogs that report a variety of health effects. Although animal data are extensive, many studies are limited by a lack of information on concurrent Ca intake, a key determinant of phosphate toxicity. Reproductive and developmental toxicity screening studies in rats, rabbits, mice, and hamsters are also available (see Table 11), although many studies are technical reports or reported only in secondary publications.
Confidence in subchronic p-RfD | M | Overall confidence in the subchronic p-RfD is medium.

Ca = calcium; L = low; M = medium; Na/K = sodium and potassium; OSP = oral sodium phosphate; P = phosphorus; p-RfD = provisional reference dose.

### 3.1.2. Derivation of the Chronic Provisional Reference Dose

As shown in Table 3A, none of the available chronic animal studies of Na/K salts of inorganic phosphates met selection criteria. Thus, the chronic p-RfD for extra-dietary exposure to Na/K salts of inorganic phosphates is derived from the same POD as the subchronic p-RfD—the LOAEL (HED) of 120 mg P/kg-day for increased incidence of nephrocalcinosis in rabbits exposed to NaH_2_PO_4_ dihydrate for 8 weeks via the diet (Ritskes-Hoitinga et al., 2004)—by applying a UF_C_ of 100 (reflecting a UF_A_ of 3, a UF_H_ of 3, a UF_L_ of 3 for using a LOAEL, and a subchronic-to-chronic extrapolation uncertainty factor [UF_S_] of 3 for use of a subchronic LOAEL as a POD).

Chronic p-RfD = POD ( HED ) ÷ UF_C_ = 120 mg P/kg-day ÷ 100 = 1 mg P/kg-day as sodium or potassium salts of inorganic phosphates

Table 19 summarizes the uncertainty factors for the chronic p-RfD for Na/K salts of inorganic phosphates. Uncertainty factors were applied in accordance with applicable guidance and methodology (U.S. EPA, 2011b, 2002).

Table 19 Uncertainty Factors for the Chronic p-RfD for Na/K Salts of Inorganic Phosphates

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rats and humans following Na/K phosphate exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b).
UF_D_ | 1 | A UF_D_ of 1 is applied as reproductive and developmental toxicity studies in rats, rabbits, mice, and hamsters are available (see Table 11), including a three-generation reproductive toxicity study, which do not signal concern for effects on fertility or development at levels below the POD for kidney effects in the principal study. The evidence base also contains short-term, subchronic, and chronic oral studies in rats and rabbits that investigate a variety of health effects. Regarding human data, numerous epidemiological studies have been conducted that investigate a variety of health effects, although methodological concerns limit their use for estimating effect levels for Na/K inorganic phosphates.
UF_H_ | 3 | A UF_H_ of 3 (10^0.5^) is applied to account for low human variability in susceptibility to increased P, due to tightly regulated homeostatic mechanisms in average individuals. Populations with pre-existing kidney disease may be more susceptible. CKD is known to increase susceptibility to inorganic phosphate toxicity, and its prevalence in the United States is around 14% (NIDDK, 2016). However, the differences in susceptibility are modest and are captured in the available human data. For instance, the prospective study by Yoon et al. (2017) found no effect of increased P intake on incidence of CKD in nondiabetic adults followed for 8 yr but did see an increased incidence in CKD in the highest P exposed quartile of diabetics. Support for using a UF_H_ of 3 is provided by the fact that the p-RfD based on Ritskes-Hoitinga et al. (2004) is more protective than a p-RfD derived based on kidney effects observed in the susceptible (diabetic) population in Yoon et al. (2017).
UF_L_ | 3 | A UF_L_ of 3 (10^0.5^) is applied because the POD is a LOAEL. The difference between LOAEL and referent group dose in the key study was ~twofold, and the incidence of nephrocalcinosis in the referent group was not significantly higher than the next lower dose (indicating the referent group approximates a NOAEL). Therefore, a full 10-fold UF was not considered appropriate.
UF_S_ | 3 | A UF_S_ of 3 (10^0.5^) was applied to address the uncertainty in extrapolating from data obtained in a study with less-than-lifetime exposure to lifetime exposure. The POD was derived from an 8-wk study in rabbits (Ritskes-Hoitinga et al., 2004), which observed increased Ca deposits in the kidney. It is possible that longer exposure durations could result in increased severity of kidney effects or effects seen at lower doses. However, a full uncertainty factor of 10 was not considered appropriate due to the narrow dose range between the POD for kidney toxicity (0.88% P) and the recommended (lower bound) P intake in rabbits to meet nutritional needs (0.22% P)(NRC, 1977).
UF_C_ | 100 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

Ca = calcium; CKD = chronic kidney disease; DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; Na/K = sodium and potassium; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor; U.S. EPA = U.S. Environmental Protection Agency.

Confidence in the chronic p-RfD for the Na/K salts of inorganic phosphates is medium, as described in Table 20.

Table 20 Confidence Descriptors for the Chronic p-RfD for Na/K Salts of Inorganic Phosphates

Confidence Categories | Designation | Discussion
Confidence in study | M | Confidence in the principal studies is medium. Ritskes-Hoitinga et al. (2004) exposed small groups (eighty per dose) of male rabbits to diets containing four different P concentrations, but only two contained at least the minimum level of P (0.4%) recommended for rabbits (Clarke et al., 1977). However, the study used a well-characterized diet and controlled for dietary Ca. In addition, the renal endpoint (nephrocalcinosis) and POD is supported by a similar study in rats by Ritskes-Hoitinga et al. (1989). Endpoints tested in the studies, although limited compared with a comprehensive toxicity study, included sensitive endpoints known or believed to be associated with phosphate intake. Endpoints included body weight/growth and feed intake, urine and fecal mineral content, weight and histology of the kidney, and femur dimensions and mineral content.
Confidence in database | M | Confidence in the database is medium. The database comprises numerous epidemiological studies including controlled exposure studies, cohort and case-control dietary intake studies, and randomized studies of OSP use for bowel preparation or constipation that report a variety of health effects. Although the database includes many human studies, these suffer from several limitations, including uncertainty in doses and relevance of dietary P (i.e., organic or inorganic P). The database also contains short-term, subchronic, and chronic oral studies in rats, rabbits, and dogs that report a variety of health effects. Although animal data are extensive, many studies are limited by a lack of information on concurrent Ca intake, a key determinant of phosphate toxicity. Reproductive and developmental toxicity screening studies in rats, rabbits, mice, and hamsters are also available (see Table 11), although many studies are technical reports or reported only in secondary publications.
Confidence in chronic p-RfD | M | Overall confidence in the chronic p-RfD is medium.

Ca = calcium; L = low; M = medium; Na/K = sodium and potassium; OSP = oral sodium phosphate; P = phosphorus; p-RfD = provisional reference dose.

### 3.1.3. Consideration of Human Data

As discussed above, information from human studies and FDA warnings, while inadequate for dose-response assessment, provides clear not-to-exceed dose estimates that may be used to assess whether the derived p-RfDs will be adequately protective for effects observed after acute and short-term durations. In addition, the relevance of the Recommended Daily Intake (RDI) of P, typical intake in the United States, and human subpopulations known to be more susceptible to phosphate toxicity warrant discussion.

Table 21 provides a comparison between the subchronic and chronic p-RfDs for Na/K salts of inorganic phosphates and effect levels identified in 1-day and short-term exposure studies in humans exposed to sodium or potassium phosphates. The table shows the study, exposure duration, estimated LOAEL, and margins of safety calculated as the ratios of the LOAEL to the subchronic p-RfD. As the table demonstrates, the p-RfD values derived from animal toxicity data provide adequate protection against effects seen in humans after acute or short-term exposure.

Table 21 Comparison between Subchronic p-RfD and LOAELs from Acute and Short-Term Human Exposures to Na/K Salts of Inorganic Phosphates

Reference and Study Type | Exposure Duration | Endpoint | LOAEL (mg P/kg-d as inorganic phosphate) | Margin of Safety (human LOAEL/subchronic p-RfD)
Nishi et al. (2015); controlled exposure | 1 d | Transient decrease in vascular endothelial function compared with pre-exposure levels | 26.49 | 7
FDA (2014); warning re: constipation therapy | 1–3 d | Laxative effect, with severe effects occurring at higher doses | 40–105 (not including dietary intake) | >10
Grimm et al. (2001); controlled exposure | 4–6 wk | GI disturbances | 50.13 | 13
Colonoscopy preparation^a^: Hurst et al. (2007) prospective cohort study, FDA (2008) warning, and numerous other studies and case reports | 1 d | Increased risk of acute renal failure/acute phosphate nephropathy; GI distress (nausea, diarrhea, bloating, vomiting) during bowel preparation for colonoscopy | 164 | 41

a Standard dose is administered in <24 hours (usually 10–12 hours apart). Dose is assumed to reflect all P sources during the day of preparation, but small amounts of P may also be consumed if allowed foods (e.g., gelatin desserts) contain P.

GI = gastrointestinal; LOAEL = lowest-observed-adverse-effect level; Na/K = sodium and potassium; P = phosphorus; p-RfD = provisional reference dose.

FDA (2014) and FDA (2008) issued health warnings pertaining to the use of OSP preparations for bowel cleansing and treatment of constipation. The 2008 warning pertained to acute kidney injury associated with bowel cleansing, and this effect and its LOAEL are shown in Table 21 with corresponding margins of safety. The 2014 FDA warning pertained to severe dehydration, electrolyte imbalances, and serious effects on the heart and kidneys, sometimes leading to death in individuals (including children) who exceed recommended daily doses of sodium phosphate preparations for constipation therapy. As discussed further in Section 2.1, the therapeutic recommendations correspond to P intakes of ~40–100 mg P/kg-day (for up to 3 days) as sodium phosphate for children >5 years of age and adults. The derived p-RfD values are well below these intake levels. FDA (2014) recommended against any use of sodium phosphate colonoscopy therapeutics for infants and children under 5 years of age unless under physician supervision; further discussion of these and other susceptible populations is presented after the discussion of nutritional requirements below.

Phosphorus is an essential nutrient that exhibits a U-shaped dose-response curve: doses below physiological requirements may lead to deleterious effects, as can doses that exceed physiological requirements. The RDI value for P is 700 mg P/day or 10 mg P/kg-day for a 70-kg adult (EFSA, 2015; IOM, 1997). Note however, that the RDI includes P from less bioavailable and organic plant and animal sources in addition to other poorly absorbed inorganic phosphate sources. Furthermore, dietary intake of P in the U.S. population is more than adequate; based on NHANES data between 2001 and 2014, McClure et al. (2017) estimated mean dietary P intake over the entire period to be 1,373 mg P/day (range of means by year was 1,324–1,414 mg P/day), or ~20 mg P/kg-day for a 70-kg adult. Although little information regarding the proportion of total dietary P load from inorganic phosphate additives (the source most relevant to this assessment) was located, one source estimated the contribution to be ~500 mg P/day (Calvo et al., 2013 as cited in Trautvetter et al., 2018). Given that the RDI of P includes both organic and inorganic sources, and extra-dietary environmental exposure to (highly bioavailable) Na/K salts of inorganic phosphate will increase P intake over and above a dietary intake that is more than adequate, the RDI is not considered to be a lower bound on the p-RfD for the Na/K salts of inorganic phosphates.

A significant proportion of the U.S. population may exhibit conditions or characteristics that increase their susceptibility to phosphate toxicity. For example, CKD impairs the body’s ability to excrete excess P, leading to hyperphosphatemia. As a result, people with CKD may be prescribed phosphate binders or instructed to reduce their intake of dietary P below the values recommended for healthy persons. Approximately 14% of the U.S. population has CKD (NIDDK, 2016). Populations on dialysis are particularly susceptible to increases in P, with one study indicating disruption of P homeostasis and activation of markers of bone resorption in patients with increased dietary intake of 100 mg/d (Tsai et al., 2021). Additional characteristics that may increase susceptibility to phosphate toxicity include female sex, low body mass index (BMI), dehydration, use of ACEIs or diuretics, and older age (FDA, 2014). Finally, as noted above, FDA recommends against the use of sodium phosphate compounds to treat constipation in infants and children under 5 years of age, unless under physician supervision, due to their enhanced susceptibility.

In deriving the p-RfDs presented herein, every effort was made to ensure that the resulting values would provide adequate protection against phosphate toxicity while working within the limitations of available data and U.S. EPA methodologies. However, Na/K salts of inorganic phosphates present unique challenges in toxicity value derivation, among them the large number of potentially susceptible individuals and high background intake of both P and inorganic phosphate additives in the U.S. population.

## 3.2. DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

### 3.2.1. Derivation of the Subchronic Provisional Reference Concentration

Relevant data with which to derive a subchronic provisional reference concentration (p-RfC) for Na/K salts of inorganic phosphates were not identified in the available literature. As noted earlier, the studies of workers involved in phosphate mining and fertilizer production (Yiin et al., 2016; Khelifi et al., 2014) are confounded by coexposure to a host of other hazardous and radioactive substances.

### 3.2.2. Derivation of the Chronic Provisional Reference Concentration

For phosphoric acid, a chronic inhalation reference concentration (RfC) of 0.01 mg/m^3^ is available in U.S. EPA’s IRIS database (U.S. EPA, 1995). This RfC is based on a subchronic study (Aranyi et al., 1988) of rats exposed to an aerosol of combustion products from burning 95% red phosphorus and 5% butyl rubber. Uncertainty with respect to the toxicology of the exposure mixture precludes using that study as the basis for a p-RfC. No relevant human or animal studies of inorganic phosphate inhalation published since the 1995 assessment were identified in the literature searches or secondary sources reviewed.

## 3.3. SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

A summary of the noncancer provisional reference values is shown in Table 22.

Table 22 Summary of Noncancer Risk Estimates for Na/K Salts of Inorganic Phosphates (Multiple CASRNs)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED) | UF_C_ | Principal Study
Subchronic p-RfD (mg P/kg-d as Na/K salts of inorganic phosphates) | Rabbit/M; | Nephrocalcinosis | 4 × 10^0^ | LOAEL | 120 | 30 | Ritskes-Hoitinga et al. (2004);
Chronic p-RfD (mg P/kg-d as Na/K salts of inorganic phosphates) | Rabbit/M; | Nephrocalcinosis | 1 × 10^0^ | LOAEL | 120 | 100 | Ritskes-Hoitinga et al. (2004);
Subchronic p-RfC (mg P/m^3^) | NDr
Chronic p-RfC (mg P/m^3^) | An RfC for phosphoric acid is available on IRIS (U.S. EPA, 1995).^a^

a Based on bronchiolar fibrosis in rats exposed by inhalation for 13 weeks.

HED = human equivalent dose; IRIS = Integrated Risk Information System; LOAEL = lowest-observed-adverse-effect level; M = male; Na/K = sodium and potassium; NDr = not determined; P = phosphorus; p-RfC = provisional inhalation reference concentration; p-RfD = provisional oral reference dose; POD = point of departure; UF_C_ = composite uncertainty factor.

## 3.4. CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Human data pertinent to the assessment of Na/K salts of inorganic phosphate carcinogenicity are limited to cohort and case-control studies of dietary P intake (see Tables 9 and 10). These studies suffer from many of the same limitations noted in dietary intake studies of noncancer endpoints, including variability in the bioavailability of different P sources and lack of data on intake for subcategories of dietary P that may be relevant to the assessment of Na/K salts of inorganic phosphates. A well-conducted, large prospective cohort study (Wilson et al., 2015) observed increased risk of prostate cancer, especially lethal and high-grade cancers, with higher dietary intake of P, after controlling for Ca, dairy, and animal protein intake. Three other dietary intake cohort studies and a case-control study examined associations with prostate cancer but did not find any significant associations. All three negative cohort studies were limited by very brief follow-up times (~8 years on average) compared with Wilson et al. (2015) (24 years).

No studies examined cancer endpoints in animals exposed to sodium or potassium salts of inorganic phosphates by oral or inhalation routes. Available genotoxicity data indicate that sodium or potassium salts of inorganic phosphates are not mutagenic and do not induce CAs or DNA damage in vitro, nor mutations in vivo (see Section 2.3.1). Wilson et al. (2015) suggested that P could influence prostate cancer progression via increases in PTH that increase bone remodeling, leading to an increase in the metastasis of prostate tumors to bone, but confirmatory or supporting data were not identified in the literature.

Although the study by Wilson et al. (2015) addressed several limitations of previous human studies, its relevance to the carcinogenicity of Na/K salts of inorganic phosphates remains uncertain, as the proportion of the dietary intake corresponding to inorganic phosphates relevant to the compounds under assessment is not known. In addition, the increases in RR of prostate cancer observed by Wilson et al. (2015) were small; adjusted RRs were ≤1.13 for all prostate cancers and ≤1.51 for lethal and high-grade cancers. Finally, animal and mechanistic data supporting an association with prostate cancer are lacking. Thus, the available data are not considered adequate to assess the carcinogenicity of Na/K salts of inorganic phosphates.

The cancer weight-of-evidence (WOE) descriptor for Na/K salts of inorganic phosphates is shown in Table 23.

Table 23 Cancer WOE Descriptor for Na/K Salts of Inorganic Phosphates

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | The available data do not support this descriptor.
“Likely to Be Carcinogenic to Humans” | NS | NA | The available data do not support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | The available data do not support this descriptor.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | Existing information is inadequate to evaluate the carcinogenicity of Na/K salts of inorganic phosphate compounds in humans or animals.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | The available data do not support this descriptor.

NA = not applicable; Na/K = sodium and potassium; NS = not selected; WOE = weight of evidence.

## 3.5. DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

Derivation of quantitative estimates of cancer risk for Na/K salts of inorganic phosphates is precluded by the lack of data demonstrating carcinogenicity associated with exposure (see Table 24).

Table 24 Summary of Cancer Risk Estimates for Na/K Salts of Inorganic Phosphates (Multiple CASRNs)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

Na/K = sodium and potassium; NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.