# 1 INTRODUCTION

In deriving provisional reference doses (p-RfDs) for sodium and potassium (Na/K) salts of inorganic phosphates, two notable departures from the traditional approach to contaminants found on contaminated sites exist: (1) the background concentrations found in humans is not zero, and (2) the background concentrations found in contaminated sites is not zero. As discussed below, phosphorus, an essential nutrient commonly found in various phosphates, exhibits a “U-shaped” dose-response curve, wherein doses above deficiency and doses below toxicity may overlap for some population subgroups. Thus, care must be taken in the interpretation and risk communication of extra-dietary exposures above those occurring in a standard American diet that may result from exposures at contaminated sites.

Phosphorus (P) is most commonly found in nature in its pentavalent form in combination with oxygen, known as phosphate or orthophosphate anion (PO_4_^3−^). Phosphorus is an essential constituent of all living organisms, and its content is quite uniform across most plant and animal tissues. Orthophosphoric acid (H_3_PO_4_) is the basic unit for all phosphates. Condensed (oligo-, pyro-, meta-, and other polyphosphates) are formed when two or more orthophosphoric acid molecules condense into a single molecule. Pyrophosphates refer to compounds with two condensed orthophosphates (P_2_O_7_)^4−^, and higher number polymers are termed polyphosphates, sometimes followed by a suffix indicating the number (e.g., [HPO_3_]_n_; thus, tri- and tetrapolyphosphates have three and four condensed phosphates, respectively). The term “metaphosphates” is used when phosphoric acid moieties form a cyclic (ring) structure. Inorganic phosphates (both ortho- and condensed polyphosphate anions) can be grouped into classes on the basis of their cations: monovalent cations (sodium [Na^+^], potassium [K^+^], ammonium [NH_4_^+^], and hydrogen [H^+^]); bivalent calcium (Ca^2+^) and magnesium (Mg^2+^); and trivalent aluminum (Al^3+^). The phosphoric acids have been grouped with the other monovalent cations on the basis of valence state of the cation.

Organic phosphates are commonly found in the form of esters as nucleotides or deoxynucleotides (e.g., adenosine monophosphate [AMP], adenosine diphosphate [ADP], adenosine triphosphate [ATP], or deoxyadenosine triphosphate [dATP]) and in deoxyribonucleic acid (DNA) and ribonucleic acid (RNA). Free orthophosphate anions can be released by the hydrolysis of the phosphoanhydride bonds in ATP or ADP. These phosphorylation and dephosphorylation reactions are the immediate storage and source of energy for many metabolic processes. ATP and ADP are often referred to as high-energy phosphates, as are the phosphagens in muscle tissue. Similar reactions exist for the other nucleoside diphosphates and triphosphates. Various other organic phosphates, such as phosphoproteins, are important in kinase cascades in signal transduction pathways, structurally as phospholipids, or as sugar-phosphates in intermediary metabolism. Plants also contain poorly absorbed phytates (inositol hexaphosphates), which are storage forms of phosphorus principally found in seeds.

This document addresses the available data on the toxicity of phosphoric acids and monovalent (sodium and potassium) salts of inorganic phosphates (see Table 1A). Aluminum, ammonium, and the divalent salts (calcium [Ca] and magnesium) are not included in this assessment because they are expected to have differing toxicity, chemistry, or toxicokinetics.

Specifically, ammonium ions are expected to exert toxic effects that are independent of the monohydrogen phosphate moiety, which would confound the hazard identification for other inorganic phosphates. In addition, ammonium phosphates exhibit different chemistry and different toxicity than Na/K phosphates: the ammonium salts are relatively unstable because ammonium hydroxide is a weaker base than metal hydroxides and ammonia can escape as a gas (Gard, 2005). Ca phosphates are much less soluble than sodium or potassium phosphates (Gard, 2005). In addition, interactions between phosphate and Ca occur both in the intestine and in the kidney. In the intestines, the phosphate ion present will transition from the monovalent dihydrogenphosphate in areas near the stomach to the divalent hydrogen phosphate ion as the pH of the intestinal contents approaches pH 7 (where calcium phosphate formation reduces absorption of both nutrients) and in the kidney (where phosphate decreases urinary Ca excretion) [as reviewed by EFSA (2015)]. These interactions do not occur with monovalent (sodium and potassium) phosphates. There is evidence that the ratio of calcium:phosphate is an important determinant of phosphate toxicity (particularly regarding bone health); thus, administration of calcium phosphate is expected to yield different toxicological effects than would administration of sodium or potassium phosphate. Finally, although magnesium phosphates are somewhat more soluble than calcium phosphates (Gard, 2005), both are most appropriately considered with other divalent salts.

Na/K salts of inorganic phosphates are used in a wide variety of applications; a few examples include in fertilizers, soaps, detergents, pH-regulating agents, antifreezing agents, adsorbents in baking powders, food nutrient supplements, and acid cleansers; in electroplating, dyeing and tanning, wastewater treatment, pottery glazing, and soldering and brazing; as a scale inhibitor in boiling water treatment; and as a fireproofing agent (NLM, 2021; OECD, 2009). In general, Na/K salts of inorganic phosphates are soluble in water (see Table 1B), and the phosphate moiety may persist indefinitely in natural waters (NLM, 2021). Polyphosphates decompose ultimately to orthophosphate in water, sodium tripolyphosphate (Na_5_P_3_O_10_) hydrolyzes to phosphonic acid (H_2_PO_3_), and tetrasodium phosphate (Na_4_P_2_O_7_) slowly hydrolyzes to orthophosphate (NLM, 2021). Sodium polyphosphates ([NaPO_3_]_n_) and sodium hexametaphosphate ([NaPO_3_]_6_) depolymerize in aqueous solution to form sodium trimetaphosphate ([NaPO_3_]_3_) and sodium orthophosphates (NLM, 2021; CIR Expert Panel, 2016).

Human exposure to Na/K salts of inorganic phosphates is likewise ubiquitous, particularly through their use as food additives and in water treatment. Although little information was located regarding the proportion of total dietary P load from monovalent salts of inorganic phosphate additives, one source estimated the contribution as ~500 mg P/day (Calvo and Uribarri, 2013 as cited in Trautvetter et al., 2018). Phosphate blends, which may include any of the compounds in Table 1A, are also used in municipal water treatment for a variety of purposes, including to control scale and corrosion; to reduce iron, lead, and copper concentrations in drinking water; and to reduce staining, scale, and objectionable tastes and odors (Willhite et al., 2013); human exposure may occur through any of these uses. Application of monovalent salts of inorganic phosphates in fertilizers and use in consumer products, such as toothpaste, water softeners, and detergents, also provide opportunities for human exposure. Finally, sodium phosphate (typically as a mixture of mono- and disodium phosphate) has been used as a bowel cleansing agent for colonoscopy preparation and as a therapeutic treatment for constipation. Its use in bowel cleansing was significantly curtailed by the U.S. Food and Drug Administration (FDA) in 2008 in response to adverse event reports (FDA, 2008).

The empirical formulas for selected Na/K salts of inorganic phosphates are shown in Table 1A. Tables 1A and 1B show the nomenclature and physicochemical properties (respectively) of the selected salts.

Table 1A Nomenclature, Chemical Formula, and Molecular Weight of Selected Na/K Salts of Inorganic Phosphates

Compound | CASRN | Empirical Formula | MW (g/mol)^a^ | MW Ratio P: Compound^b^ | Physical State^a^
Orthophosphoric acid | 7664-38-2 | H_3_PO_4_ | 97.995 | 0.31608 | Colorless crystals or viscous liquid
Polyphosphoric acid | 8017-16-1 | (HPO_3_)_n_; molecular weights vary | | | Clear, viscous liquid
Sodium dihydrogen orthophosphate (monosodium phosphate) | 7558-80-7 | NaH_2_PO_4_ | 119.977 | 0.25817 | White or colorless crystalline powder
Sodium monohydrogen orthophosphate (disodium phosphate) | 7558-79-4 | Na_2_HPO_4_ | 141.96 | 0.21819 | Colorless crystals or white hygroscopic powder
Sodium orthophosphate (trisodium phosphate) | 7601-54-9 | Na_3_PO_4_ | 163.94 | 0.18893 | Colorless crystals
Sodium dihydrogen pyrophosphate (disodium diphosphate) | 7758-16-9 | Na_2_H_2_P_2_O_7_ | 221.94 | 0.27912 | White crystalline powder
Sodium pyrophosphate (tetrasodium diphosphate) | 7722-88-5 | Na_4_P_2_O_7_ | 265.94 | 0.23294 | Colorless transparent crystals or white powder
Sodium tripolyphosphate (pentasodium triphosphate) | 7758-29-4 | Na_5_P_3_O_10_ | 367.86 | 0.25260 | White powder
Sodium trimetaphosphate | 7785-84-4 | (NaPO_3_)_3_ | 305.882^d^ | 0.30378 | White crystals or white crystalline powder^c^
Sodium polyphosphate | 68915-31-1 | (NaPO_3_)_n_, where n = 10–15; molecular weights vary | | | Clear hygroscopic glass
Sodium hexametaphosphate | 10124-56-8 | (NaPO_3_)_6_ | 611.763 | 0.30378 | Clear hygroscopic glass
Potassium dihydrogen phosphate (monopotassium phosphate) | 7778-77-0 | KH_2_PO_4_ | 136.085 | 0.22761 | Colorless crystals or white granular powder
Potassium monohydrogen phosphate (dipotassium phosphate) | 7758-11-4 | K_2_HPO_4_ | 174.18 | 0.17783 | White crystals or colorless granules or powder
Potassium phosphate (tripotassium phosphate) | 7778-53-2 | K_3_PO_4_ | 212.265^d^ | 0.14389 | Colorless or white hygroscopic crystals or granules^d^
Potassium pyrophosphate (tetrapotassium diphosphate) | 7320-34-5 | K_4_P_2_O_7_ | 330.33^c^ | 0.18753 | Colorless crystals or white, very hygroscopic powder^d^
Potassium tripolyphosphate (pentapotassium triphosphate) | 13845-36-8 | K_5_P_3_O_10_ | 448.403^d^ | 0.20723 | White, very hygroscopic powder or granules^d^

a NLM (2021) unless otherwise specified.

b MW of P = 30.974 g/mol (NLM, 2021).

c CIR Expert Panel (2016).

d PubChem (2018).

MW = molecular weight; Na/K = sodium and potassium; P = phosphorus.

Table 1B Physicochemical Properties of Selected Na/K Salts of Inorganic Phosphates^a,^ ^b^

Compound | Chemical Formula | Melting Point (°C) | Density (g/cm^3^ at 25°C) | pH (unitless) | pKa (unitless) | Solubility in Water (mg/L at 25°C)
Orthophosphoric acid | H_3_PO_4_ | 42.4 | 1.87 | 1.5 (0.1 N aqueous solution) | pK_1_ = 2.15, pK_2_ = 7.09, pK_3_ = 12.32 | 5.48 × 10^6^ at 20°C
Polyphosphoric acid | (HPO_3_)_n_ | Varies | | | | Soluble
Sodium dihydrogen orthophosphate (monosodium phosphate) | NaH_2_PO_4_ | 200 (decomposes) | 2.36 | 4.5 (1% aqueous solution) | 6.8–7.2 | 9.49 × 10^5^
Sodium monohydrogen orthophosphate (disodium phosphate) | Na_2_HPO_4_ | 35 (dodecahydrate) | 1.7 (approximate) | 9.1 (1% aqueous solution at 25°C) | pK_1_ = 2.15 | 1.18 × 10^5^
Sodium orthophosphate (trisodium phosphate) | Na_3_PO_4_ | 1,583 (anhydrous)^b^ 75 (dodecahydrate)^c^ | 2.54 | 11.5–11.9 (0.1–1% solution) | NV | 1.45 × 10^5^
Sodium dihydrogen pyrophosphate | Na_2_H_2_P_2_O_7_ | 220 (decomposes) | 1.86 (hexahydrate) | NV | NV | 3.5 × 10^5^ at 40°C
Tetrasodium pyrophosphate (tetrasodium diphosphate) | Na_4_P_2_O_7_ | 988 (anhydrous) 79.5 (decahydrate)^c^ | 2.534 | 10.2 (1% solution) | NV | 6.7 × 10^4^
Sodium tripolyphosphate (pentasodium triphosphate) | Na_5_P_3_O_10_ | 622 | NV | 9.7–9.8 (1% solution at 25°C) | NV | 2.0 × 10^5^
Sodium trimetaphosphate | (NaPO_3_)_3_ | 53 (hexahydrate) | 1.786 (hexahydrate) | NV | NV | 2.2 × 10^5^
Sodium polyphosphate | (NaPO_3_)_n_ | Varies | | | | Soluble in water^d^
Sodium hexametaphosphate | (NaPO_3_)_6_ | 628 | NV | NV | NV | Slowly soluble in water
Potassium dihydrogen orthophosphate (monopotassium phosphate) | KH_2_PO_4_ | 253 | 2.34 | 4.4–4.7 | NV | 2.5 × 10^5^
Potassium monohydrogen orthophosphate (dipotassium phosphate) | K_2_HPO_4_ | NV/decomposes | 0.6 to ~0.7^e^ | 8.8 (1% solution) | NV | 1.68 × 10^6^
Potassium phosphate (tripotassium phosphate) | K_3_PO_4_ | NV | NV | 11.5–12.3 (1% solution)^f^ | NV | Freely soluble in water^f^
Tetrapotassium pyrophosphate (tetrapotassium diphosphate) | K_4_P_2_O_7_ | 1,090 | NV | 10.0–10.8 (1% solution)^f^ | NV | 1.87 × 10^6^ ^f^
Potassium tripolyphosphate (pentapotassium triphosphate) | K_5_P_3_O_10_ | NV | NV | 9.2–10.5 (1% solution)^f^ | NV | Very soluble in water^f^

a Octanol-water partition coefficient, Henry’s law constant, soil adsorption coefficient, atmospheric OH rate constant, and atmospheric half-life are not applicable to inorganic phosphates.

b NLM (2021), unless otherwise specified.

c U.S. EPA (2012).

d CIR Expert Panel (2016).

e OECD (2006), potassium.

f PubChem (2018).

Na/K = sodium and potassium; NV = not available; pKa = acid dissociation constant.

A summary of available subchronic and chronic toxicity values for phosphorus from U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Subchronic or Chronic Toxicity Values and Adequate Intake Values for Na/K Salts of Inorganic Phosphates (Multiple CASRNs)

Source (parameter)^a,^ ^b^ | Phosphorus Form | Value (applicability) | Notes | Reference^c^
Noncancer
IRIS (RfC) | Phosphoric acid (PA) | 0.01 mg/m^3^ | Basis: Bronchiolar fibrosis in a 13-wk rat study. This RfC is for aerosols of PA and P oxidation products and does not apply to elemental P or other forms of P, such as phosphorus salts. | U.S. EPA (1995)
HEAST | NA | NV | NA | U.S. EPA (2011a)
DWSHA | NA | NV | NA | U.S. EPA (2018)
ATSDR | NA | NV | NA | ATSDR (2018)
EFSA (AI) | P | AI by age:; 7–11 mo: 200 mg/d; 1–3 yr: 300 mg/d; 4–10 yr: 600 mg/d; 11–17 yr: 800 mg/d; Adults and pregnant/lactating women: 700 mg/d | Phosphorus from all sources, expressed as P. | EFSA (2015)
IOM (UL) | P | Children: 3,000 mg/d; Adults ≤70 yr: 4,000 mg/d; Adults >70 yr: 3,000 mg/d; Pregnant women: 3,500 mg/d; Lactating women: 4,000 mg/d | The maximum level of daily nutrient intake that is likely to pose no risk of adverse effects. The UL represents total intake from food, water, and supplements. | IOM (1997)
WHO (MTDI) | P | 70 mg/kg | Maximum intake of P across all sources; based on nephrocalcinosis in rats. | WHO (1982)
CalEPA (REL, chronic inhalation) | PA | 7 μg/m^3^ | Basis: Bronchiolar fibrosis in rats. | CalEPA (2017, 2008)
OSHA (PEL) | PA | 1 mg/m^3^ | 8-h TWA for general industry, construction, and shipyard employment. | OSHA (2020, 2017a, 2017b)
NIOSH (REL) | PA | 1 mg/m^3^ | TWA for up to a 10-h workday during a 40-h workweek. | NIOSH (2016)
ACGIH (TWA-TLV) | PA | 1 mg/m^3^ | Basis: Upper respiratory tract, eye, and skin irritation. | ACGIH (2016)
USAPHC (air-MEG) | PA | 1-yr negligible: 0.068 mg/m^3^ | Based on IRIS. | U.S. APHC (2013)
USAPHC (soil-MEG) | PA | 1-yr negligible: 1,000,000 mg/kg | Basis: Noncancer. | U.S. APHC (2013)
Cancer
IRIS | NA | NV | NA | U.S. EPA (2020)
HEAST | NA | NV | NA | U.S. EPA (2011a)
DWSHA | NA | NV | NA | U.S. EPA (2018)
NTP | NA | NV | NA | NTP (2016)
CalEPA | NA | NV | NA | CalEPA (2020, 2019)
ACGIH | NA | NV | NA | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; EFSA = European Food Safety Authority; HEAST = Health Effects Assessment Summary Tables; IOM = Institute of Medicine; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; USAPHC = U.S. Army Public Health Command; WHO = World Health Organization.

b Parameters: AI = adequate intake; MEG = military exposure guideline; MTDI = maximum tolerable daily intake; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = reference concentration; TLV = threshold limit value; TWA = time-weighted average; UL = tolerable upper intake level.

c Reference date is the publication date for the database and not the date the online source was accessed.

NA = not applicable; Na/K = sodium and potassium; NV = not available; P = phosphorus; PA = phosphoric acid.

Non-date-limited literature searches were conducted in October 2017 and updated most recently in February 2022 for studies relevant to the derivation of provisional toxicity values for inorganic phosphates, including phosphoric acid (PA) and selected Na/K salts (names and CASRNs shown in Table 1A). The literature search updated conducted in February 2022, post External Peer Review, did not identify any studies which would affect the quantitative conclusions of the PPRTV assessment.

Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE (including TSCATS1), and Web of Science. Secondary key words were applied in EndNote to help prioritize results for screening. EndNote was used to manually screen items published since the previous version of this PPRTV in 2009. Studies were then imported into SWIFT Review software to identify those references most likely to be applicable to a human health risk assessment, and resulting studies were imported to EndNote. In brief, SWIFT Review has preset literature search strategies (“filters”) developed by information specialists that can be applied to identify studies that are more likely to be useful for identifying human health content from those that likely do not (e.g., environmental fate). Only studies meeting the populations, exposures, comparators, and outcomes (PECO) criteria are cited. The following databases were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), Japan Existing Chemical Data Base (JECDB), National Institute for Occupational Safety and Health (NIOSH), National Pesticide Information Retrieval System (NPIRS), National Toxicology Program (NTP), Organisation for Economic Co-operation and Development (OECD) Existing Chemicals Database, OECD Screening Information Data Set (SIDS) High Production Volume Chemicals via International Programme on Chemical Safety (IPCS) INCHEM, Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).