# APPENDIX C REFERENCES

Abaskharoun R; Depew W; Vanner S. (2007). Changes in renal function following administration of oral sodium phosphate or polyethylene glycol for colon cleansing before colonoscopy. Can J Gastroenterol 21: 227–231.17431511
Abuduli M; Ohminami H; Otani T; Kubo H; Ueda H; Kawai Y; Masuda M; Yamanaka-Okumura H; Sakaue H; Yamamoto H; Takeda E; Taketani Y. (2016). Effects of dietary phosphate on glucose and lipid metabolism. Am J Physiol Endocrinol Metab 310: E526–E538. 10.1152/ajpendo.00234.2015 26786774
ACGIH (American Conference of Governmental Industrial Hygienists). (2016). Phosphoric acid [TLV/BEI]. In 2016 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices (pp. 49). Cincinnati, OH. https://www.acgih.org/forms/store/ProductFormPublic/2016-tlvs-and-beis
ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Alonso A; Nettleton JA; Ix JH; de Boer IH; Folsom AR; Bidulescu A; Kestenbaum BR; Chambless LE; Jacobs DR Jr. (2010). Dietary phosphorus, blood pressure, and incidence of hypertension in the atherosclerosis risk in communities study and the multiethnic study of atherosclerosis. Hypertension 55: 776–784. 10.1161/HYPERTENSIONAHA.109.143461 20083730
Anderson JJ. (2013). Potential health concerns of dietary phosphorus: cancer, obesity, and hypertension [Review]. Ann N Y Acad Sci 1301: 1–8. 10.1111/nyas.12208 23848306
Aranyi C; Henry MC; Vana SC; Gibbons RD; Iverson WO. (1988). Effects of multiple intermittent inhalation exposures to red phosphorus/butyl rubber obscurant smokes in Sprague-Dawley rats. Inhal Toxicol 1: 65–78.
Atkinson RJ; Hunter JO. (2002). Aphthous ulceration in the colon after sodium phosphate bowel preparation for colonoscopy [Abstract]. Gut 50: A72–A72.
Atkinson RJ; Save V; Hunter JO. (2005). Colonic ulceration after sodium phosphate bowel preparation [Letter]. Am J Gastroenterol 100: 2603–2605. 10.1111/j.1572-0241.2005.00305_11.x 16279928
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Minimal risk levels (MRLs). June 2018. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR).
Beloosesky Y; Grinblat J; Weiss A; Grosman B; Gafter U; Chagnac A. (2003). Electrolyte disorders following oral sodium phosphate administration for bowel cleansing in elderly patients. Arch Intern Med 163: 803–808. 10.1001/archinte.163.7.803 12695271
Belsey J. (2008). Acute phosphate nephropathy--comment on Sica et al [Letter]. Am J Gastroenterol 103: 800. 10.1111/j.1572-0241.2007.01612_2.x
Beyea A; Block C; Schned A. (2007). Acute phosphate nephropathy following oral sodium phosphate solution to cleanse the bowel for colonoscopy. Am J Kidney Dis 50: 151–154. 10.1053/j.ajkd.2007.03.005 17591536
Bounds W; Skinner J; Carruth BR; Ziegler P. (2005). The relationship of dietary and lifestyle factors to bone mineral indexes in children. J Am Diet Assoc 105: 735–741. 10.1016/j.jada.2005.02.046 15883550
Brot C; Jørgensen N; Madsen OR; Jensen LB; Sørensen OH. (1999). Relationships between bone mineral density, serum vitamin D metabolites and calcium:phosphorus intake in healthy perimenopausal women. J Intern Med 245: 509–516.10363752
Brown RB; Razzaque MS. (2015). Dysregulation of phosphate metabolism and conditions associated with phosphate toxicity. Chemosphere 4: 705. 10.1038/bonekey.2015.74
Brown RB; Razzaque MS. (2018). Phosphate toxicity and tumorigenesis. Biochim Biophys Acta Rev Cancer 1869: 303–309. 10.1016/j.bbcan.2018.04.007 29684520
Brunelli SM; Feldman HI; Latif SM; Gupta M; Weiner MG; Lewis JD. (2009). A comparison of sodium phosphosoda purgative to polyethylene glycol bowel preparations prior to colonoscopy. Fam Med 41: 39–45.19132571
Brunelli SM; Lewis JD; Gupta M; Latif SM; Weiner MG; Feldman HI. (2007). Risk of kidney injury following oral phosphosoda bowel preparations. J Am Soc Nephrol 18: 3199–3205. 10.1681/ASN.2007040440 17978309
CalEPA (California Environmental Protection Agency). (2008). TSD for noncancer RELs Appendix D.3 Chronic RELs and toxicity summaries using the previous version of the Hot Spots Risk Assessment guidelines (OEHHA 1999). Sacramento, CA: California Office of Environmental Health Hazard Assessment:: OEHHA. http://oehha.ca.gov/media/downloads/crnr/appendixd3final.pdf
CalEPA (California Environmental Protection Agency). (2017). OEHHA chemical database. Sacramento, CA: Office of Environmental Health Hazard Assessment. Retrieved from https://oehha.ca.gov/chemicals
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
CalEPA (California Environmental Protection Agency). (2020). OEHHA chemical database. Sacramento, CA: Office of Environmental Health Hazard Assessment. Retrieved from https://oehha.ca.gov/chemicals
Calvo MS; Tucker KL. (2013). Is phosphorus intake that exceeds dietary requirements a risk factor in bone health? [Review]. Ann N Y Acad Sci 1301: 29–35. 10.1111/nyas.12300 24472074
Candeal E; Caldas YA; Guillén N; Levi M; Sorribas V. (2017). Intestinal phosphate absorption is mediated by multiple transport systems in rats. Am J Physiol Gastrointest Liver Physiol 312: G355–G366. 10.1152/ajpgi.00244.2016 28232455
Chan JM; Pietinen P; Virtanen M; Malila N; Tangrea J; Albanes D; Virtamo J. (2000). Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes Control 11: 859–867. 10.1023/a:1008947201132 11075876
Chang AR; Anderson C. (2017). Dietary phosphorus intake and the kidney [Review]. Annu Rev Nutr 37: 321–346. 10.1146/annurev-nutr-071816-064607 28613982
Chang AR; Lazo M; Appel LJ; Gutiérrez OM; Grams ME. (2014). High dietary phosphorus intake is associated with all-cause mortality: results from NHANES III. Am J Clin Nutr 99: 320–327. 10.3945/ajcn.113.073148 24225358
Chang AR; Miller ER; Anderson CA; Juraschek SP; Moser M; White K; Henry B; Krekel C; Oh S; Charleston J; Appel LJ. (2017). Phosphorus additives and albuminuria in early stages of CKD: A randomized controlled trial. Am J Kidney Dis 69: 200–209. 10.1053/j.ajkd.2016.08.029 27865566
Cheng J; Tao K; Shuai X; Gao J. (2016). Sodium phosphate versus polyethylene glycol for colonoscopy bowel preparation: an updated meta-analysis of randomized controlled trials [Review]. Surgical Endoscopy 30: 4033–4041. 10.1007/s00464-015-4716-6 26679172
CIR Expert Panel (Cosmetic Ingredient Review Expert Panel). (2016). Safety assessment of phosphoric acid and simple salts as used in cosmetics. Cosmetic Ingredient Review. https://www.cir-safety.org/supplementaldoc/safety-assessment-phosphoric-acid-and-simple-salts-used-cosmetics-0
Clarke HE; Coates ME; Eva JK; Ford DJ; Milner CK; O'Donoghue PN; Scott PP; Ward RJ. (1977). Dietary standards for laboratory animals: report of the Laboratory Animals Centre Diets Advisory Committee. Lab Anim 11: 1–28.402499
Connor A; Sykes L; Roberts IS; Weston CE. (2008). Acute phosphate nephropathy after sodium phosphate preparations. BMJ 337: a182. 10.1136/bmj.a182 18640953
Coton T; Luciano L; Marcelko A. (2011). Colic lesions induced by Colokit (R) preparation. Clinics and Research in Hepatology and Gastroenterology 35: 509–510. 10.1016/j.clinre.2011.04.003 21820987
Datta PK; Frazer AC; Sharratt M; Sammons HG. (1962). Biological effects of food additives: II. Sodium pyrophosphate. J Sci Food Agric 13: 556–566. 10.1002/jsfa.2740131102
Driman DK; Preiksaitis HG. (1998). Colorectal inflammation and increased cell proliferation associated with oral sodium phosphate bowel preparation solution. Hum Pathol 29: 972–978. 10.1016/S0046-8177(98)90203-9 9744314
Dymsza HA; Reussner G Jr; Thiessen R Jr. (1959). Effect of normal and high intakes of orthophosphate and metaphosphate in rats. J Nutr 69: 419–428. 10.1093/jn/69.4.419 13819016
ECHA (European Chemicals Agency). (2005). Dipotassium hydrogenorthophosphate: Screening for reproductive/developmental toxicity. 001 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/14974/1
ECHA (European Chemicals Agency). (2008). Orthophosphoric acid: Toxicological information: Short-term repeated dose toxicity: Oral. 003 Key | Experimental result (JS member). (231-633-2). https://echa.europa.eu/cs/registration-dossier/-/registered-dossier/15531/7/6/2/?documentUUID=10e6b289-cbcb-4644-acc2-8d387f3a70f1#
ECHA (European Chemicals Agency). (2018). European chemicals agency. Available online at https://echa.europa.eu/
EFSA (European Food Safety Authority). (2005). Opinion of the scientific panel on dietetic products, nutrition and allergies on a request from the commission related to the tolerable upper intake level of phosphorus. EFSA J 233: 1–19.
EFSA (European Food Safety Authority). (2015). Scientific opinion on dietary reference values for phosphorus. EFSA panel on dietetic products, nutrition and allergies (NDA). EFSA J 13: 1–54.
Elliott P; Kesteloot H; Appel LJ; Dyer AR; Ueshima H; Chan Q; Brown IJ; Zhao L; Stamler J; Group IC R. (2008). Dietary phosphorus and blood pressure: international study of macro- and micro-nutrients and blood pressure. Hypertension 51: 669–675. 10.1161/hypertensionaha.107.103747 18250363
Elmståhl S; Gullberg B; Janzon L; Johnell O; Elmståhl B. (1998). Increased incidence of fractures in middle-aged and elderly men with low intakes of phosphorus and zinc. Osteoporos Int 8: 333–340. 10.1007/s001980050072 10024903
Erben RG; Andrukhova O. (2017). FGF23-Klotho signaling axis in the kidney [Review]. Bone 100: 62–68. 10.1016/j.bone.2016.09.010 27622885
FASEB/LSRO (Federation of American Societies for Experimental Biology, Life Sciences Research Office). (1975). Evaluation of the health aspects of phosphates as food ingredients. (ETICBACK/5777). Washington, DC: Food and Drug Administration.
FDA (U.S. Food and Drug Administration). (2008). Information for healthcare professionals: oral sodium phosphate (OSP) products for bowel cleansing (marketed as Visicol and OsmoPrep, and oral sodium products available without a prescription). Available online at https://www.fda.gov/Drugs/DrugSafety/ucm103354.htm
FDA (U.S. Food and Drug Administration). (2014). FDA drug safety communication. FDA warns of possible harm from exceeding recommended dose of over-the-counter sodium phosphate products to treat constipation. U.S. FDA. https://www.fda.gov/Drugs/DrugSafety/ucm380757.htm
FDRL (Food and Drug Research Laboratories Inc.). (1973a). Teratologic evaluation of FDA 71-46 (sodium tripolyphosphate, anhydrous) (pp. 14 PP). (ETICBACK/6186). Washington, DC: Food and Drug Administration.
FDRL (Food and Drug Research Laboratories Inc.). (1973b). Teratologic evaluation of FDA 71-61 (sodium acid pyrophosphate). (ETICBACK/6191). Washington, DC: Food and Drug Administration.
FDRL (Food and Drug Research Laboratories Inc.). (1974a). Teratologic evaluation of FDA 73-1, tetrasodium pyrophosphate, anhydrous, in mice and rats. (PB-245 534). Washington, DC: Food and Drug Administration.
FDRL (Food and Drug Research Laboratories Inc.). (1974b). Teratologic evaluation of FDA 73-3 (sodium hexametaphosphate) in mice and rats. (ETICBACK/6206). Washington, DC: Food and Drug Administration.
FDRL (Food and Drug Research Laboratories Inc.). (1975). Teratologic evaluation of FDA 73-65, monopotassium phosphate, in mice and rats. (ETICBACK/6130). Washington, DC: Food and Drug Administration.
Fine KD; Ogunji F; Florio R; Porter J; Ana CS. (1998). Investigation and diagnosis of diarrhea caused by sodium phosphate. Dig Dis Sci 43: 2708–2714. 10.1023/A:1026611629624 9881503
Gard DR. (2005). Phosphoric acids and phosphates. In Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. https://onlinelibrary.wiley.com/doi/10.1002/0471238961.1608151907011804.a01.pub2
Grimm M; Muller A; Hein G; Funfstuck R; Jahreis G. (2001). High phosphorus intake only slightly affects serum minerals, urinary pyridinium crosslinks and renal function in young women. Eur J Clin Nutr 55: 153–161. 10.1038/sj.ejcn.1601131 11305263
Gross P; Six I; Kamel S; Massy MD. (2014). Vascular toxicity of phosphate in chronic kidney disease-beyond vascular calcification. Circ J 78: 2339–2346.25077548
Gutiérrez OM. (2013). The connection between dietary phosphorus, cardiovascular disease, and mortality: where we stand and what we need to know [Review]. Adv Nutr 4: 723–729. 10.3945/an.113.004812 24228204
Haas S; Andersen LM; Sommer T. (2014). Randomized controlled trial comparing Moviprep® and Phosphoral® as bowel cleansing agents in patients undergoing colonoscopy. Tech Coloproctol 18: 929–935. 10.1007/s10151-014-1198-9 25038914
Haraikawa M; Tanabe R; Sogabe N; Sugimoto A; Kawamura Y; Michigami T; Hosoi T; Goseki-Sone M. (2012). A study of the association between serum bone-specific alkaline phosphatase and serum phosphorus concentration or dietary phosphorus intake. J Nutr Sci Vitaminol 58: 442–445.23419404
Heaney RP; Nordin BE. (2002). Calcium effects on phosphorus absorption: Implications for the prevention and co-therapy of osteoporosis. J Am Coll Nutr 21: 239–244. 10.1080/07315724.2002.10719216 12074251
Heppe DH; Medina-Gomez C; Hofman A; Franco OH; Rivadeneira F; Jaddoe VW. (2013). Maternal first-trimester diet and childhood bone mass: the Generation R Study. Am J Clin Nutr 98: 224–232. 10.3945/ajcn.112.051052 23719545
Hitchman AJ; Hasany SA; Hitchman A; Harrison JE; Tam C. (1979). Phophate-induced renal calcification in the rat. Can J Physiol Pharmacol 57: 92–97. 10.1139/y79-013 427649
Hodge HC. (1964). Toxicity studies on phosphates. Food Cosmet Toxicol 2: 147–154.14173237
Hong SH; Park SJ; Lee S; Kim S; Cho MH. (2015). Biological effects of inorganic phosphate: potential signal of toxicity [Review]. J Toxicol Sci 40: 55–69. 10.2131/jts.40.55 25743563
Huang CL. (2010). Regulation of ion channels by secreted Klotho: Mechanisms and implications. Kidney Int 77: 855–860. 10.1038/ki.2010.73 20375979
Hurst FP; Bohen EM; Osgard EM; Oliver DK; Das NP; Gao SW; Abbott KC. (2007). Association of oral sodium phosphate purgative use with acute kidney injury. J Am Soc Nephrol 18: 3192–3198. 10.1681/ASN.2007030349 17978311
Huttunen MM; Tillman I; Viljakainen HT; Tuukkanen J; Peng Z; Pekkinen M; Lamberg-Allardt CJ. (2007). High dietary phosphate intake reduces bone strength in the growing rat skeleton. J Bone Miner Res 22: 83–92. 10.1359/jbmr.061009 17042736
IOM (Institute of Medicine). (1997). Dietary reference intakes for calcium, phosphorus, magnesium, vitamin D, and fluoride. Washington, DC: National Academy Press. http://www.nap.edu/catalog.php?record_id=5776
Itkonen ST; Karp HJ; Kemi VE; Kokkonen EM; Saarnio EM; Pekkinen MH; Kärkkäinen MU; Laitinen EK; Turanlahti MI; Lamberg-Allardt CJ. (2013). Associations among total and food additive phosphorus intake and carotid intima-media thickness–a cross-sectional study in a middle-aged population in Southern Finland. Nutr J 12: 94. 10.1186/1475-2891-12-94 23841978
Ito S; Ishida H; Uenishi K; Murakami K; Sasaki S. (2011). The relationship between habitual dietary phosphorus and calcium intake, and bone mineral density in young Japanese women: a cross-sectional study. Asia Pac J Clin Nutr 20: 411–417.21859660
Jain N; Elsayed EF. (2013). Dietary phosphate: What do we know about its toxicity? [Review]. J Nephrol 26: 856–864. 10.5301/jn.5000242 23475467
Kan WC; Wang HY; Chien CC; Tan CK; Lin CY; Su SB. (2012). Intermediate bioelectrolyte changes after phospho-soda or polyethylene glycol precolonoscopic laxatives in a population undergoing health examinations. Nephrol Dial Transplant 27: 752–757. 10.1093/ndt/gfr189 21617195
Katsumata S; Masuyama R; Uehara M; Suzuki K. (2005). High-phosphorus diet stimulates receptor activator of nuclear factor-kappaB ligand mRNA expression by increasing parathyroid hormone secretion in rats. Br J Nutr 94: 666–674. 10.1079/BJN20051552 16277767
Katsumata S; Matsuzaki H; Uehara M; Suzuki K. (2015). Effects of dietary calcium supplementation on bone metabolism, kidney mineral concentrations, and kidney function in rats fed a high-phosphorus diet. J Nutr Sci Vitaminol 61: 195–200. 10.3177/jnsv.61.195 26052152
Kesse E; Bertrais S; Astorg P; Jaouen A; Arnault N; Galan P; Hercberg S. (2006). Dairy products, calcium and phosphorus intake, and the risk of prostate cancer: results of the French prospective SU.VI.MAX (Supplémentation en Vitamines et Minéraux Antioxydants) study. Br J Nutr 95: 539–545.16512941
Kesse E; Boutron-Ruault MC; Norat T; Riboli E; Clavel-Chapelon F; Group EN. (2005). Dietary calcium, phosphorus, vitamin D, dairy products and the risk of colorectal adenoma and cancer among French women of the E3N-EPIC prospective study. Int J Cancer 117: 137–144. 10.1002/ijc.21148 15880532
Khelifi M; Zarrouk A; Nury T; Hamed H; Saguem S; Salah RB; Riedinger JM; Lizard G. (2014). Cytokine and eicosanoid profiles of phosphate mine workers. J Toxicol Sci 39: 465–474.24849681
Khurana A; Mclean L; Atkinson S; Foulks CJ. (2008). The effect of oral sodium phosphate drug products on renal function in adults undergoing bowel endoscopy. Arch Intern Med 168: 593–597. 10.1001/archinte.168.6.593 18362251
Kim SJ; Rim KT; Kim HY; Yang JS. (2010). Mutagenicity of octane and tetrasodium pyrophosphate in bacterial reverse mutation (Ames) test [Letter]. J Toxicol Sci 35: 555–562.20686342
Koshihara M; Katsumata S; Uehara M; Suzuki K. (2005). Effects of dietary phosphorus intake on bone mineralization and calcium absorption in adult female rats. Biosci Biotechnol Biochem 69: 1025–1028. 10.1271/bbb.69.1025 15914926
Kuro OM. (2019). The Klotho proteins in health and disease. Nature Revisions, Nephrology 15: 27–44. 10.1038/s41581-018-0078-3
Kwak SM; Kim JS; Choi Y; Chang Y; Kwon MJ; Jung JG; Jeong C; Ahn J; Kim HS; Shin H; Ryu S. (2014). Dietary intake of calcium and phosphorus and serum concentration in relation to the risk of coronary artery calcification in asymptomatic adults. Arterioscler Thromb Vasc Biol 34: 1763–1769. 10.1161/ATVBAHA.114.303440 24925973
Layton JB; Klemmer PJ; Christiansen CF; Bomback AS; Baron JA; Sandler RS; Kshirsagar AV. (2014). Sodium phosphate does not increase risk for acute kidney injury after routine colonoscopy, compared with polyethylene glycol. Clin Gastroenterol Hepatol 12: 1514–1521.e1513. 10.1016/j.cgh.2014.01.034 24486407
Lee AW; Cho SS. (2015). Association between phosphorus intake and bone health in the NHANES population. Nutr J 14: 28. 10.1186/s12937-015-0017-0 25856461
Lee GJ; Marks J. (2015). Intestinal phosphate transport: a therapeutic target in chronic kidney disease and beyond? [Review]. Pediatr Nephrol 30: 363–371. 10.1007/s00467-014-2759-x 24496589
Lee KJ; Kim KS; Kim HN; Seo JA; Song SW. (2014). Association between dietary calcium and phosphorus intakes, dietary calcium/phosphorus ratio and bone mass in the Korean population. Nutr J 13: 114. 10.1186/1475-2891-13-114 25496564
Lee SW; Bang CS; Park TY; Suk KT; Baik GH; Kim DJ. (2017). Split-dose bowel preparation for colonoscopy: 2 liters polyethylene glycol with ascorbic acid versus sodium picosulfate versus oral sodium phosphate tablets. Korean J Gastroenterol 70: 89–95. 10.4166/kjg.2017.70.2.89 28830134
Bionetics Litton. (1975a). Mutagenic evaluation of compound FDA 71-46, sodium tripolyphosphate. (EMICBACK/29961).
Litton Bionetics. (1975b). Mutagenic evaluation of compound FDA 73-1, tetrasodium pyrophosphate. (EMICBACK/29943).
Litton Bionetics. (1975c). Mutagenic evaluation of compound FDA 73-2, monosodium phosphate anhydrous powdered, FCC grade. (EMICBACK/29919).
Litton Bionetics. (1975d). Mutagenic evaluation of compound FDA 73-3, sodium hexametaphosphate. (PB-245486).
Ma HL; Qin MJ; Qi LW; Wu G; Shu P. (2007). Improved quality evaluation of Radix Salvia miltiorrhiza through simultaneous quantification of seven major active components by high-performance liquid chromatography and principal component analysis. Biomed Chromatogr 21: 931–939. 10.1002/bmc.836 17474138
MacKay EM; Oliver J. (1935). Renal damage following the ingestion of a diet containing an excess of inorganic phosphate. J Exp Med 61: 319–334. 10.1084/jem.61.3.319 19870361
Manukyan MN; Tolan K; Severge U; Attaallah W; Kebudi A; Cingi A. (2011). Prospective randomized comparison of oral sodium phosphate and sennoside A+B calcium lavage for colonoscopy preparation. Surg Laparosc Endosc Percutan Tech 21: 90–93. 10.1097/SLE.0b013e31820e8793 21471799
Markowitz GS; Nasr SH; Klein P; Anderson H; Stack JI; Alterman L; Price B; Radhakrishnan J; D'Agati VD. (2004). Renal failure due to acute nephrocalcinosis following oral sodium phosphate bowel cleansing. Hum Pathol 35: 675–684. 10.1016/j.humpath.2003.12.005 15188133
Markowitz GS; Perazella MA. (2009). Acute phosphate nephropathy [Review]. Kidney Int 76: 1027–1034. 10.1038/ki.2009.308 19675530
Markowitz GS; Stokes MB; Radhakrishnan J; D'Agati VD. (2005). Acute phosphate nephropathy following oral sodium phosphate bowel purgative: an underrecognized cause of chronic renal failure. J Am Soc Nephrol 16: 3389–3396. 10.1681/ASN.2005050496 16192415
Marks J; Debnam ES; Unwin RJ. (2010). Phosphate homeostasis and the renal-gastrointestinal axis [Review]. Am J Physiol Renal Physiol 299: F285–F296. 10.1152/ajprenal.00508.2009 20534868
Marshall JB. (2014). Should oral sodium phosphate solution return as the first-line preparation for colonoscopy? [Editorial]. Clin Gastroenterol Hepatol 12: 1522–1524. 10.1016/j.cgh.2014.02.015 24534545
Matsuzaki H; Fuchigami M; Miwa M. (2010). Dietary magnesium supplementation suppresses bone resorption via inhibition of parathyroid hormone secretion in rats fed a high-phosphorus diet. Magnes Res 23: 126–130. 10.1684/mrh.2010.0212 20810356
Matsuzaki H; Katsumata S; Masuyama R; Uehara M; Nakamura K; Suzuki K. (2002). Sex differences in kidney mineral concentrations and urinary albumin excretion in rats given high-phosphorus feed. Biosci Biotechnol Biochem 66: 1737–1739. 10.1271/bbb.66.1737 12353637
Matsuzaki H; Kikuchi T; Kajita Y; Masuyama R; Uehara M; Goto S; Suzuki K. (1999). Comparison of various phosphate salts as the dietary phosphorus source on nephrocalcinosis and kidney function in rats. J Nutr Sci Vitaminol 45: 595–608.10683811
Matsuzaki H; Uehara M; Suzuki K; Liu QL; Sato S; Kanke Y; Goto S. (1997). High phosphorus diet rapidly induces nephrocalcinosis and proximal tubular injury in rats. J Nutr Sci Vitaminol 43: 627–641.9530615
McClure ST; Chang AR; Selvin E; Rebholz CM; Appel LJ. (2017). Dietary sources of phosphorus among adults in the United States: Results from NHANES 2001-2014. Nutrients 9. 10.3390/nu9020095
Medoff J; Katz S; Malik P; Pambianco D; Pruitt R; Poulos J; Rank J; Rose M. (2004). Open-label, dose-ranging pilot study of 4 weeks of low-dose therapy with sodium phosphate tablets in chronically constipated adults. Clin Ther 26: 1479–1491. 10.1016/j.clinthera.2004.09.007 15531010
Méndez RO; Gómez MA; López AM; González H; Wyatt CJ. (2002). Effects of calcium and phosphorus intake and excretion on bone density in postmenopausal women in Hermosillo, Mexico. Ann Nutr Metab 46: 249–253. 10.1159/000066497 12464724
Menon MC; Ix JH. (2013). Dietary phosphorus, serum phosphorus, and cardiovascular disease [Review]. Ann N Y Acad Sci 1301: 21–26. 10.1111/nyas.12283 24117725
Michaud DS; Spiegelman D; Clinton SK; Rimm EB; Willett WC; Giovannucci E. (2000). Prospective study of dietary supplements, macronutrients, micronutrients, and risk of bladder cancer in US men. Am J Epidemiol 152: 1145–1153. 10.1093/aje/152.12.1145 11130620
Murtaugh MA; Filipowicz R; Baird BC; Wei G; Greene T; Beddhu S. (2012). Dietary phosphorus intake and mortality in moderate chronic kidney disease: NHANES III. Nephrol Dial Transplant 27: 990–996. 10.1093/ndt/gfr367 21810769
Nadkarni GN; Uribarri J. (2014). Phosphorus and the kidney: What is known and what is needed [Review]. Adv Nutr 5: 98–103. 10.3945/an.113.004655 24425728
Nakamura K; Hori Y; Nashimoto M; Okuda Y; Miyazaki H; Kasai Y; Yamamoto M. (2004). Dietary calcium, sodium, phosphorus, and protein and bone metabolism in elderly Japanese women: a pilot study using the duplicate portion sampling method. Nutrition 20: 340–345. 10.1016/j.nut.2003.12.004 15043848
NIDDK (National Institute of Diabetes and Digestive and Kidney Diseases). (2016). Kidney disease statistics for the United States. Available online at https://www.niddk.nih.gov/health-information/health-statistics/kidney-disease
NIOSH (National Institute for Occupational Safety and Health). (2016). Phosphoric acid. NIOSH pocket guide to chemical hazards. Atlanta, GA: Centers for Disease Control and Prevention, U.S. Department of Health, Education and Welfare. https://www.cdc.gov/niosh/npg/npgd0506.html
Nishi T; Shuto E; Ogawa M; Ohya M; Nakanishi M; Masuda M; Katsumoto M; Yamanaka-Okumura H; Sakai T; Takeda E; Sakaue H; Taketani Y. (2015). Excessive dietary phosphorus intake impairs endothelial function in young healthy men: a time- and dose-dependent study. J Med Invest 62: 167–172. 10.2152/jmi.62.167 26399342
NLM (National Library of Medicine). (2021). Hazardous substances data bank [Database]. Bethesda, MD. Retrieved from https://www.nlm.nih.gov/databases/download/hsdb.html
Noori N; Kalantar-Zadeh K; Kovesdy CP; Bross R; Benner D; Kopple JD. (2010a). Association of dietary phosphorus intake and phosphorus to protein ratio with mortality in hemodialysis patients. Clin J Am Soc Nephrol 5: 683–692. 10.2215/CJN.08601209 20185606
Noori N; Sims JJ; Kopple JD; Shah A; Colman S; Shinaberger CS; Bross R; Mehrotra R; Kovesdy CP; Kalantar-Zadeh K. (2010b). Organic and inorganic dietary phosphorus and its management in chronic kidney disease. Iran J Kidney Dis 4: 89–100.20404416
NRC (National Research Council). (1977). Nutrient requirements of rabbits: second revised edition, 1977. Washington, DC: The National Academies Press. 10.17226/35
NRC (National Research Council). (1995). Nutrient requirements of laboratory animals (Fourth revised ed.). Washington, DC: The National Academies Press. 10.17226/4758
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
OECD (Organisation for Economic Co-operation and Development). (2006). SIDS initial assessment report for SIAM 23. Dipotassium hydrogenphosphate (DKP).
OECD (Organisation for Economic Co-operation and Development). (2009). SIDS initial assessment profile. Phosphoric acid.
Ori Y; Herman M; Tobar A; Chernin G; Gafter U; Chagnac A; Izhak OB; Korzets A. (2008). Acute phosphate nephropathy-an emerging threat. Am J Med Sci 336: 309–314. 10.1097/MAJ.0b013e318167410c 18854672
Orias M; Mahnensmith RL; Perazella MA. (1999). Extreme hyperphosphatemia and acute renal failure after a phosphorus-containing bowel regimen. Am J Nephrol 19: 60–63.10085452
OSHA (Occupational Safety & Health Administration). (2017a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC: U.S. Department of Labor. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2017b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. (OSHA standard 1910.1000, 29 CFR). Washington, DC: U.S. Department of Labor. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992
OSHA (Occupational Safety & Health Administration). (2020). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
Patel V; Nicar M; Emmett M; Asplin J; Maguire JA; Santa Ana CA; Fordtran JS. (2009). Intestinal and renal effects of low-volume phosphate and sulfate cathartic solutions designed for cleansing the colon: Pathophysiological studies in five normal subjects. Am J Gastroenterol 104: 953–965. 10.1038/ajg.2008.124 19240703
Pelham RW; Russell RG; Padgett EL; Reno FE; Cleveland M. (2009). Safety of oral sulfates in rats and dogs contrasted with phosphate-induced nephropathy in rats. Int J Toxicol 28: 99–112. 10.1177/1091581809335124 19482834
PubChem. (2018). PubChem. Available online at https://pubchem.ncbi.nlm.nih.gov/
Raitakari OT; Celermajer DS. (2000). Flow-mediated dilatation. Br J Clin Pharmacol 50: 397–404.11069434
Ramezani Tehrani F; Moslehi N; Asghari G; Gholami R; Mirmiran P; Azizi F. (2013). Intake of dairy products, calcium, magnesium, and phosphorus in childhood and age at menarche in the Tehran Lipid and Glucose Study. PLoS ONE 8: e57696. 10.1371/journal.pone.0057696 23451261
Rejchrt S; Bures J; Siroký M; Kopácová M; Slezák L; Langr F. (2004). A prospective, observational study of colonic mucosal abnormalities associated with orally administered sodium phosphate for colon cleansing before colonoscopy. Gastrointest Endosc 59: 651–654. 10.1016/S0016-5107(04)00158-0 15114307
Ritskes-Hoitinga J; Grooten HN; Wienk KJ; Peters M; Lemmens AG; Beynen AC. (2004). Lowering dietary phosphorus concentrations reduces kidney calcification, but does not adversely affect growth, mineral metabolism, and bone development in growing rabbits. Br J Nutr 91: 367–376. 10.1079/BJN20041065 15005822
Ritskes-Hoitinga J; Lemmens AG; Danse LH; Beynen AC. (1989). Phosphorus-induced nephrocalcinosis and kidney function in female rats. J Nutr 119: 1423–1431. 10.1093/jn/119.10.1423 2585132
Ritter SC; Slatopolsky E. (2016). Phosphate toxicity in CKD: The killer among us. Clin J Am Soc Nephrol 11: 1088–1100. 10.2215/CJN.11901115 26912542
Russmann S; Lamerato L; Marfatia A; Motsko SP; Pezzullo JC; Olds G; Jones JK. (2007). Risk of impaired renal function after colonoscopy: A cohort study in patients receiving either oral sodium phosphate or polyethylenglycol [Abstract]. Pharmacoepidemiol Drug Saf 16: S230–S231. 10.1002/pds.1461
Samuel TM; Thomas T; Finkelstein J; Bosch R; Rajendran R; Virtanen SM; Srinivasan K; Kurpad AV; Duggan C. (2013). Correlates of anaemia in pregnant urban South Indian women: A possible role of dietary intake of nutrients that inhibit iron absorption. Public Health Nutr 16: 316–324. 10.1017/S136898001200119X 22575487
Schneider P; Ober KM; Ueberberg H. (1981). Contribution to the phosphate-induced nephropathy in the dog. Comparative light and electron microscopic investigations on the proximal tubule after oral application of K2HPO4, Na2HPO4, KCl and NaCl. Exp Pathol 19: 53–65.7262273
Seo DS; Kwon M; Sung HJ; Park CB. (2011a). Acute oral or dermal and repeated dose 90-day oral toxicity of tetrasodium pyrophosphate in Spraque [sic] Dawley (SD) rats. Environmental Health and Toxicology 26. 10.5620/eht.2011.26.e2011014
Seo EH; Kim TO; Kim TG; Joo HR; Park MJ; Park J; Park SH; Yang SY; Moon YS. (2011b). Efficacy and tolerability of split-dose PEG compared with split-dose aqueous sodium phosphate for outpatient colonoscopy: a randomized, controlled trial. Dig Dis Sci 56: 2963–2971. 10.1007/s10620-011-1772-1 21656179
Seol DC; Hong SN; Kim JH; Sung IK; Park HS; Lee JH; Shim CS. (2010). Change in renal function after sodium phosphate preparation for screening colonoscopy. World J Gastroenterol 16: 2010–2016.20419839
Shibata MA; Sano M; Shirai T; Imaida K; Fukushima S. (1993). Epithelial hyperplasia in the renal papilla and pelvis but not the urinary-bladder of male F344 rats associated with dietary-sodium phosphates after uracil exposure. Toxicol Appl Pharmacol 121: 303–312. 10.1006/taap.1993.1158 8346547
Shuto E; Taketani Y; Tanaka R; Harada N; Isshiki M; Sato M; Nashiki K; Amo K; Yamamoto H; Higashi Y; Nakaya Y; Takeda E. (2009). Dietary phosphorus acutely impairs endothelial function. J Am Soc Nephrol 20: 1504–1512. 10.1681/ASN.2008101106 19406976
Singal AK; Rosman AS; Post JB; Bauman WA; Spungen AM; Korsten MA. (2008). The renal safety of bowel preparations for colonoscopy: a comparative study of oral sodium phosphate solution and polyethylene glycol. Aliment Pharmacol Ther 27: 41–47. 10.1111/j.1365-2036.2007.03558.x 17956596
Slee TM; Vleming LJ; Valentijn RM. (2008). Renal failure due to acute phosphate nephropathy. Neth J Med 66: 438–441.19011271
Tani Y; Sato T; Yamanaka-Okumura H; Yamamoto H; Arai H; Sawada N; Genjida K; Taketani Y; Takeda E. (2007). Effects of prolonged high phosphorus diet on phosphorus and calcium balance in rats. J Clin Biochem Nutr 40: 221–228. 10.3164/jcbn.40.221 18398500
Tavani A; Bertuccio P; Bosetti C; Talamini R; Negri E; Franceschi S; Montella M; La Vecchia C. (2005). Dietary intake of calcium, vitamin D, phosphorus and the risk of prostate cancer. Eur Urol 48: 27–33. 10.1016/j.eururo.2005.03.023 15967248
Tobias JH; Steer CD; Emmett PM; Tonkin RJ; Cooper C; Ness AR. (2005). Bone mass in childhood is related to maternal diet in pregnancy. Osteoporos Int 16: 1731–1741. 10.1007/s00198-005-1912-6 15905998
Trautvetter U; Ditscheid B; Jahreis G; Glei M. (2018). Habitual intakes, food sources and excretions of phosphorus and calcium in three german study collectives. Nutrients 10: 171. 10.3390/nu10020171 29393923
Tsai TY; Hsu PF; Wu CH; Yang YL; Chen SC; Huang SS; Chan WL; Lin SJ; Chen JW; Pan JP; Charng MJ; Chen YH; Wu TC; Lu TM; Huang PH; Cheng HM; Huang CC; Sung SH; Lin YJ; Leu HB. (2021). Association between phosphate and long-term outcome in CAD patients underwent coronary intervention. Sci Rep 11: 20080. 10.1038/s41598-021-99518-z 34635717
Tseng M; Breslow RA; Graubard BI; Ziegler RG. (2005). Dairy, calcium, and vitamin D intakes and prostate cancer risk in the National Health and Nutrition Examination Epidemiologic Follow-up Study cohort. Am J Clin Nutr 81: 1147–1154. 10.1093/ajcn/81.5.1147 15883441
U.S. APHC (U.S. Army Public Health Command). (2013). Environmental health risk assessment and chemical exposure guidelines for deployed military personnel. (Technical guide 230, 2013 revision). Aberdeen Proving Ground, MD. https://phc.amedd.army.mil/PHC%20Resource%20Library/TG230-DeploymentEHRA-and-MEGs-2013-Revision.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1995). Integrated Risk Information System (IRIS) chemical assessment summary for phosphoric acid. Washington, DC: Office of Research and Development, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0697_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Health effects assessment summary tables (HEAST) for superfund [EPA Report]. Washington, DC. https://epaheast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11 [Computer Program]. Washington, DC. Retrieved from https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimationprogram-interface
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories tables [EPA Report]. (EPA822F18001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2020). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
Uribarri J. (2013). Dietary phosphorus and kidney disease [Review]. Ann N Y Acad Sci 1301: 11–19. 10.1111/nyas.12201 23876096
van Lee L; Heyworth J; Mcnaughton S; Iacopetta B; Clayforth C; Fritschi L. (2011). Selected dietary micronutrients and the risk of right- and left-sided colorectal cancers: a case-control study in Western Australia. Ann Epidemiol 21: 170–177. 10.1016/j.annepidem.2010.10.005 21109455
Watts DA; Lessells AM; Penman ID; Ghosh S. (2002). Endoscopic and histologic features of sodium phosphate bowel preparation-induced colonic ulceration: Case report and review. Gastrointest Endosc 55: 584–587. 10.1067/mge.2002.122582 11923780
Weiner ML; Salminen WF; Larson PR; Barter RA; Kranetz JL; Simon GS. (2001). Toxicological review of inorganic phosphates [Review]. Food Chem Toxicol 39: 759–786. 10.1016/S0278-6915(01)00028-X 11434984
Whiting SJ; Boyle JL; Thompson A; Mirwald RL; Faulkner RA. (2002). Dietary protein, phosphorus and potassium are beneficial to bone mineral density in adult men consuming adequate dietary calcium. J Am Coll Nutr 21: 402–409. 10.1080/07315724.2002.10719242 12356781
WHO (World Health Organization). (1982). Phosphoric acid and phosphate salts. In Toxicological evaluation of certain food additives and contaminants. (WHO Food Additive Series 17). Geneva, Switzerland: International Programme on Chemical Safety.
Willhite CC; Ball GL; Bhat VS. (2013). Emergency do not consume/do not use concentrations for blended phosphates in drinking water. Hum Exp Toxicol 32: 241–259. 10.1177/0960327112459207 23060411
Wilson KM; Shui IM; Mucci LA; Giovannucci E. (2015). Calcium and phosphorus intake and prostate cancer risk: a 24-y follow-up study. Am J Clin Nutr 101: 173–183. 10.3945/ajcn.114.088716 25527761
Yakut M; Cinar K; Seven G; Cetınkaya H; Bahar K. (2010). The efficacy and safety of colonoscopy preparation with oral sodium phosphate in elderly patients. Turk J Gastroenterol 21: 140–145. 10.4318/tjg.2010.0072 20872327
Yamamoto KT; Robinson-Cohen C; de Oliveira MC; Kostina A; Nettleton JA; Ix JH; Nguyen H; Eng J; Lima JA; Siscovick DS; Weiss NS; Kestenbaum B. (2013). Dietary phosphorus is associated with greater left ventricular mass. Kidney Int 83: 707–714. 10.1038/ki.2012.303 23283134
Yiin JH; Daniels RD; Kubale TL; Dunn KL; Stayner LT. (2016). A study update of mortality in workers at a phosphate fertilizer production facility. Am J Ind Med 59: 12–22. 10.1002/ajim.22542 26523937
Yilmaz S; Unal F; Yüzbasioglu D; Celik M. (2014). DNA damage in human lymphocytes exposed to four food additives in vitro. Toxicol Ind Health 30: 926–937. 10.1177/0748233712466132 23188648
Yin J; Dwyer T; Riley M; Cochrane J; Jones G. (2010). The association between maternal diet during pregnancy and bone mass of the children at age 16. Eur J Clin Nutr 64: 131–137. 10.1038/ejcn.2009.117 19756026
Yoon CY; Park JT; Jhee JH; Noh J; Kee YK; Seo C; Lee M; Cha MU; Kim H; Park S; Yun HR; Jung SY; Han SH; Yoo TH; Kang SW. (2017). High dietary phosphorus density is a risk factor for incident chronic kidney disease development in diabetic subjects: a community-based prospective cohort study. Am J Clin Nutr 106: 311–321. 10.3945/ajcn.116.151654 28592606