# APPENDIX B DATA TABLES

Table B-1 Significant Effects in Female Weanling Wistar Rats Administered Inorganic Phosphate (as Ca[H_2_PO_4_]_2_ Alone or with NaH_2_PO_4_) in the Diet for 6 Weeks^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 530 (0.5% P in diet; referent) | 1,100 (1% P in diet)
Kidney Ca concentration (μg/g) | 460 ± 167^b^ | 3,350 ± 470^*^ (+628%)^c^
Kidney wet weight (g) | 1.87 ± 0.04 | 2.16 ± 0.11^*^ (+16%)

a Hitchman et al. (1979).

b Mean ± SE.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from referent group at p < 0.05, based on two-sided t-test performed for this review.

Ca = calcium; Ca[H_2_PO_4_]_2_ = Calcium phosphate; NaH_2_PO_4_ = monosodium phosphate; P = phosphorus; SE = standard error.

Table B-2 Significant Effects in Male Wistar Rats Administered Inorganic Phosphate (as CaHPO_4_ and KH_2_PO_4_) in the Diet for 8 Weeks^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 510 (0.6% P in diet; referent) | 980 (1.2% P in diet) | 1,400 (1.8% P in diet)
Serum PTH (units not specified) | 300 ± 166^b^ | 583 ± 272 (+94%)^c^ | 2,190 ± 821^**^ (+630%)^c^
Femur length (cm) | 3.7 ± 0.14 | 3.6 ± 0.19 (−3%) | 3.4 ± 0.15^**^ (−8%)
Femur bmc; final (g) | 0.35 ± 0.03 | 0.33 ± 0.03 (−6%) | 0.28 ± 0.03^**^ (−20%)
Femur bmd; final (g/cm^3^) | 0.23 ± 0.02 | 0.21 ± 0.02^**^ (−9%) | 0.19 ± 0.02^**^ (−17%)
Femur; distal metaphysis
Total bone bmc (g) | 11.3 ± 0.90 | 9.6 ± 0.92^**^ (−15%) | 9.8 ± 1.12^**^ (−13%)
Total bone CSA (mm^2^) | 19.9 ± 2.3 | 17.9 ± 1.3^*^ (−10%) | 17.3 ± 2.4^**^ (−13%)
Cortical bmc (g) | 8.04 ± 0.46 | 7.34 ± 0.64^*^ (−9%) | 7.03 ± 0.76^**^ (−13%)
Cortical CSA (mm^2^) | 7.7 ± 0.3 | 7.1 ± 0.2^**^ (−8%) | 7.6 ± 0.3^*^ (−1%)
Femur; midshaft
Total bone bmc (g) | 8.5 ± 0.67 | 7.9 ± 0.54^*^ (−7%) | 7.0 ± 0.69^**^ (−18%)
Total bone CSA (mm^2^) | 10.8 ± 1.3 | 9.8 ± 0.8^*^ (−9%) | 9.4 ± 0.7^**^ (−13%)
Cortical bmd (g/cm^3^) | 1,289.2 ± 12.5 | 1,291.0 ± 15.6 (+0%) | 1,250.1 ± 19.2^**^ (−3%)
Cortical bmc (g) | 7.74 ± 0.56 | 7.18 ± 0.49^*^ (−7%) | 6.32 ± 0.69^**^ (−18%)
Cortical CSA (mm^2^) | 6.0 ± 0.5 | 5.6 ± 0.4^*^ (−7%) | 5.0 ± 0.5^**^ (−17%)
Cortical thickness (mm) | 0.72 ± 0.43 | 0.70 ± 0.35 (−3%) | 0.65 ± 0.46^**^ (−10%)
Femur; mechanical competence
Ultimate strength (N) | 117 ± 8.6 | 104 ± 7.4 (−10%) | 88.3 ± 18^**^ (−24%)
Yield point | 100 ± 9.2 | 80 ± 20 (−20%) | 64 ± 25^**^ (−36%)
Tibia; trabecular bone
Bone volume (mm^3^) | 2.5 ± 0.3^†^ | 1.2 ± 0.2 (−52%) | 1.7 ± 0.4 (−32%)
Bone surface (mm^2^) | 141 ± 8.1^†^ | 75 ± 14 (−47%) | 97 ± 18 (−31%)
Structure model index | 2.1 ± 0.10^†^ | 2.1 ± 0.03 (+0%) | 1.8 ± 0.05 (−14%)
Connective structures per unit volume (mm^−3^) | 46.4 ± 14 | 37.9 ± 0.79 (−18%) | 69.9 ± 2.28 (+51%)
Tibia; cortical bone
Total cross-sectional area (mm^2^) | 5.3 ± 0.24^‡^ | 4.5 ± 0.14 (−15%) | 4.0 ± 0.06 (−25%)
Tibia; mechanical competence
Ultimate strength (N) | 118 ± 18^‡^ | 104 ± 8.7 (−12%) | 83 ± 14 (−30%)
Stiffness (N/mm) | 332 ± 51^‡^ | 295 ± 23 (−11%) | 251 ± 49 (−24%)
Toughness (N-M × 10^−3^) | 103 ± 17^‡^ | 71 ± 18 (−32%) | 62 ± 23 (−40%)
Yield point | 74 ± 19^†^ | 81 ± 18 (+9%) | 56 ± 20 (−24%)

a Huttunen et al. (2007).

b Mean ± SD.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from the referent group at p ≤ 0.05, based on pairwise analyses performed by the study authors.

** p ≤ 0.01.

† Significant difference across all groups by ANOVA at p ≤ 0.05, as reported by the study authors.

‡ p ≤ 0.01.

ANOVA = analysis of variance; bmc = bone mineral content; CaHPO_4_ = calcium phosphate; CSA = cross-sectional area; KH_2_PO_4_ = monopotassium phosphate; N = newtons; N-M = newton meters (units of toughness); P = phosphorus; PTH = parathyroid hormone; SD = standard deviation.

Table B-3 Significant Effects in Female Wistar Rats Administered Inorganic Phosphate (as KH_2_PO_4_) in the Diet for 6 Weeks^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 270 (0.5% P in diet; referent) | 800 (1.5% P in diet)
Body-weight gain (g) | 32.27 ± 2.69^b^ | 28.65 ± 2.88 (−11%)^c^
Ca absorption (mg/d) | 14.29 ± 1.52 | 5.57 ± 3.23^*^ (−61%)
P balance
Absorption (mg/d) | 38.78 ± 1.30 | 148.40 ± 5.41^*^ (+283%)
Urinary excretion (mg/d) | 29.36 ± 5.83 | 115.59 ± 6.86^*^ (+294%)
Serum osteocalcin (ng/mL) | 20.05 ± 1.50 | 27.88 ± 2.53^*^ (+39%)
Urinary deoxypyridinoline (nmol/mmol creatinine) | 70.76 ± 5.44 | 89.60 ± 7.16^*^ (+27%)
Fifth lumbar bmd (mg/cm^2^) | 78.02 ± 0.77 | 71.87 ± 0.88^*^ (−8%)

a Koshihara et al. (2005).

b Mean ± SEM for n = five per group.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from referent group at p < 0.05, based on analyses performed by the study authors.

bmd = bone mineral density; Ca = calcium; KH_2_PO_4_ = monopotassium phosphate; P = phosphorus; SEM = standard error of the mean.

Table B-4 Effects in Female Wistar RIV:TOX Rats Administered Inorganic Phosphate in the Diet (as NaH_2_PO_4_ Dihydrate) for 28 Days (Experiment 1)^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 390 (0.41% P in diet; referent) | 580 (0.60% P in diet)
Body weight (g) | 89.4 ± 10.4^b^ | 90.7 ± 8.4 (+1%)^c^
Urine pH
Study Days 0–2 | 9.2 ± 0.1 | 8.5 ± 0.8^**^ (−8%)
Study Days 13–15 | 8.3 ± 0.7 | 7.5 ± 0.6^*^ (−10%)
Study Days 26–28 | 8.8 ± 0.6 | 7.3 ± 0.3^**^ (−17%)
Urine albumin (mg/d)
Study Days 13–15 | 0.52 ± 0.17 | 1.45 ± 0.71^**^ (+179%)
Study Days 26–28 | 0.56 ± 0.29 | 0.99 ± 0.40^*^ (+77%)
Urine urea (mg/100 g body weight × d)
Study Days 13–15 | 157.8 ± 24.6 | 185.3 ± 33.9^*^ (+17%)
Study Days 26–28 | 177.7 ± 21.8 | 189.4 ± 28.5 (+7%)
Relative kidney weight (g/100 g body weight) | 0.41 ± 0.04 | 0.52 ± 0.08^**^ (+27%)
Kidney P (%) | 1.5 ± 0.2 | 3.7 ± 1.3^**^ (+2%)
Kidney Ca (%) | 0.4 ± 0.2 | 5.7 ± 3.0^**^ (+5%)
Kidney Mg (%) | 0.10 ± 0.00 | 0.23 ± 0.07^**^ (+0.1%)
Nephrocalcinosis | 2/6^d^ (33%) | 16/16 (100%)
Mean severity | 0.5 | 2.7^†^

a Ritskes-Hoitinga et al. (1989).

b Mean ± SD.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100, or for data presented as percent, it is percent difference = (treatment mean % − control mean %).

d Number affected/number examined (% incidence).

* Significantly different from referent group at p < 0.05, based on analyses performed by the study authors.

** p < 0.01.

† The distribution of histological scores was significantly different from that of the reference group at p < 0.05, based on analyses (Mann-Whitney U test) performed by the study authors.

Ca = calcium; Mg = magnesium; NaH_2_PO_4_ = monosodium phosphate; P = phosphorus; SD = standard deviation.

Table B-5 Effects in Female Wistar RIV:TOX Rats Administered Inorganic Phosphate in the Diet (as NaH_2_PO_4_ Dihydrate) for 28 Days (Experiment 2)^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 410 (0.41% P in diet; referent) | 580 (0.61% P in diet)
Body weight (g) | 87.2 ± 4.1^b^ | 88.5 ± 6.5 (+1%)^c^
Urine pH
Study Days 0–2 | 8.9 ± 0.4 | 8.2 ± 0.4^**^ (−8%)
Study Days 13–15 | 8.6 ± 0.6 | 7.7 ± 0.7^**^ (−10%)
Study Days 26–28 | 8.5 ± 0.8 | 7.9 ± 0.9 (−7%)
Urine albumin (mg/d)
Study Days 0–2 | 0.15 ± 0.07 | 0.10 ± 0.03^*^ (−33%)
Study Days 13–15 | 0.22 ± 0.11 | 0.74 ± 0.55^**^ (+236%)
Study Days 26–28 | 0.35 ± 0.15 | 0.60 ± 0.33 (+71%)
Serum Ca (mg/100 mL) | 10.21 ± 0.14 | 9.63 ± 0.45^*^ (−6%)
Serum Mg (mg/100 mL) | 2.04 ± 0.15 | 1.66 ± 0.19^*^ (−18%)
Relative kidney weight (g/100 g body weight)
Study Day 14 | 0.45 ± 0.02 | 0.49 ± 0.07 (+9%)
Study Day 28 | 0.37 ± 0.03 | 0.46 ± 0.14 (+24%)
Kidney P (%)
Study Day 14 | 1.2 ± 0.0 | 2.7 ± 1.1^**^ (+2%)
Study Day 28 | 1.3 ± 0.2 | 2.4 ± 1.1 (+1%)
Kidney Ca (%)
Study Day 14 | 0.1 ± 0.0 | 3.4 ± 1.9^**^ (+3%)
Study Day 28 | 0.9 ± −0.8 | 3.5 ± 2.1^*^ (+3%)
Kidney Mg (%)
Study Day 14 | 0.09 ± 0.00 | 0.18 ± 0.09^*^ (+0.09%)
Study Day 28 | 0.08 ± 0.00 | 0.13 ± 0.04^*^ (+0.05%)
Nephrocalcinosis
Study Day 14 | 5/6^d^ (83%) | 6/6^d^ (100%)
Mean severity | 1.0 | 2.8^†^
Study Day 28 | 5/6 (83%) | 6/6 (100%)
Mean severity | 1.5 | 2.5^†^

a Ritskes-Hoitinga et al. (1989).

b Mean ± SD.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100, or for data presented as percent, it is percent difference = (treatment mean % − control mean %).

d Number affected/number examined (% incidence).

* Significantly different from referent group at p < 0.05, based on analyses performed by the study authors.

** p < 0.01.

† The distribution of histological scores was significantly different from that of the reference group at p < 0.05, based on analyses performed by the study authors.

Ca = calcium; Mg = magnesium; NaH_2_PO_4_ = monosodium phosphate; P = phosphorus; SD = standard deviation.

Table B-6 Significant Effects in Male NZW Rabbits Administered Inorganic Phosphate (as NaH_2_PO_4_ Dihydrate) in the Diet for 8 Weeks^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 77 (0.2% P in diet) | 150 (0.45% P in diet) | 290 (0.85% P in diet)
Initial body weight (kg) | 1.77 ± 0.10 | 1.77 ± 0.10^b,c^ | 1.77 ± 0.10 (+0%)
Final body weight (kg) | 2.42 ± 0.41 | 2.66 ± 0.27 | 2.41 ± 0.29 (−9%)
Feed intake (g/d) | 66.9 ± 9.4 | 73.1 ± 7.6 | 68.9 ± 9.5 (−6%)
Urine pH Days 20–23 | 9.42^b^ ± 0.16 | 9.36 ± 0.15 | 8.20 ± 0.35^*^ (−1,450%)^d^
Urine pH Days 48–51 | 9.23^b^ ± 0.34 | 9.35 + 0.23 | 8.04 + 0.30^*^ (−1,620%)^d^
Urinary Ca | 96.8 + 16.7 | 49.6 + 23.5 | 1.48 + 0.43^*^ (−3,350%)
Urinary P | 22.4 + 5.8 | 73.4 + 12.6 | 238 + 23^*^ (+326%)
Serum P (Day 28/Day 56) | 1.92 + 0.19/1.80 + 0.28 | 2.06 + 0.17/1.84 + 0.12 | 2.51 + 0.63/2.29 + 0.57 (+17.9%/+19.7%)
Serum Ca (Day 28/Day 56) | 2.97 + 0.34/3.16 + 0.09 | 2.81 + 0.29/3.21 + 0.41 | 2.55 + 0.23/2.71 + 0.20 (−9.0%/−16.6%)
Serum Mg (Day 28/Day 56) | 0.63 + 0.09/0.64 + 0.01 | 0.68 + 0.07/0.63 + 0.18 | 0.65 + 0.23/0.64 + 0.18 (−4.4%/−2.7%)
Kidney Ca concentration (% dry weight) | 0.07 ± 0.04 | 0.34 ± 0.65 | 1.40 ± 1.51^*^ (+412%)
Kidney P concentration (% dry weight) | 1.50 + 0.10 | 1.61 + 0.15 | 2.08 + 0.60 (+29.2%)
Absolute kidney wet weight (g) | 7.34 + 1.41 | 8.71 + 1.63 | 8.12 + 1.17 (−6.77)
Absolute kidney dry weight (g) | 1.44 ± 0.19 | 1.60 ± 0.25 | 1.46 ± 0.16 (−9%)
Relative kidney weight (% body weight) | 0.31 ± 0.05 | 0.33 ± 0.06 | 0.34 ± 0.05 (+3%)
Diaphysis of femur Mg concentration
% dry weight | 0.40 ± 0.02 | 0.42 ± 0.01 | 0.48 ± 0.04^*^ (+14%)
% ash | 0.52 ± 0.03 | 0.55 ± 0.02 | 0.64 ± 0.05^*^ (+16%)
Epiphysis of femur Mg concentration
% dry weight | 0.24 ± 0.02 | 0.23 ± 0.04 | 0.29 ± 0.03^*^ (+26%)
% ash | 0.47 ± 0.02 | 0.47 ± 0.03 | 0.59 ± 0.07^*^ (+26%)
mg/cm^3^ | 2.26 ± 0.28 | 2.30 ± 0.42 | 2.90 ± 0.76^*^ (+26%)
Incidence and severity^e^ of renal Ca deposits in the cortex (von Kossa stained)
0 | 6/8 (75%) | 5/8^f^ (63%) | 0/8^e^ (0%)^†^
1 | 2/8 (25%) | 2/8 (25%) | 3/8 (38%)^†^
2 | 0/8 (0%) | 1/8 (13%) | 4/8 (50%)^†^
3 | 0/8 (0%) | 0/8 (0%) | 1/8 (13%)^†^
Incidence and severity^e^ of renal Ca deposits in the cortex (hematoxylin-eosin stained)
0 | 6/8 (75%) | 6/8^f^ (75%) | 0/8^e^ (0%)^†^
1 | 2/8 (25%) | 1/8 (13%) | 3/8 (38%)^†^
2 | 0/8 (0%) | 1/8 (13%) | 4/8 (50%)^†^
3 | 0/8 (0%) | 0/8 (0%) | 1/8 (13%)^†^
Incidence and severity^e^ of renal Ca deposits in the medulla (von Kossa stained)
0 | 5/8 (63%) | 0/8 (0 %) | 0/8 (0%)
1 | 2/8 (25%) | 1/8 (13%) | 1/8 (13%)
2 | 1/8 (13%) | 6/8 (75%) | 7/8 (88%)
3 | 0/8 (0%) | 0/8 (0%) | 0/8 (0%)
Incidence and severity^e^ of renal Ca deposits in the medulla (hematoxylin-eosin stained)
0 | 3/8 (38%) | 0/8 (0%) | 0/8 (0%)
1 | 3/8 (38%) | 3/8 (38%) | 3/8 (38%)
2 | 2/8 (25%) | 5/8 (63%) | 5/8 (63%)
3 | 0/8 (0%) | 0/8 (0%) | 0/8 (0%)

a Ritskes-Hoitinga et al. (2004).

b Mean ± SD for n = eight per group.

c Value in parentheses is percent change relative to control = ([treatment mean − control mean] ÷ control mean) × 100.

d Significantly different from the two other groups (p < 0.05), based on analyses performed by the study authors (Tukey B test).

e Calcification score: 0 (no calcium deposits); 1 (a few calcified deposits); 2 (multiple deposits); 3 (band of calcification throughout entire section).

f Number affected/number examined (% incidence).

* Significantly different from the referent group at p < 0.05, based on analyses performed by the study authors.

† The distribution of histological scores was significantly different from the reference group at p < 0.05, based on analyses performed by the study authors.

Ca = calcium; SP = monosodium phosphate; P = phosphorus; SD = standard deviation; NZW = New Zealand White

Table B-7 Significant Effects in Male Wistar Rats Administered Inorganic Phosphate (as KH_2_PO_4_) in the Diet for 4 Weeks^a^

Effects (units) | Dose in mg P/kg-d (% P in diet)
Effects (units) | 250 (0.3% P in diet; referent) | 450 (0.6% P in diet) | 670 (0.9% P in diet) | 920 (1.2% P in diet) | 1,000 (1.5% P in diet)
Body-weight gain (g/4 wk) | 95 ± 5.1^b^ | 82.3 ± 0.9 (−13%)^c^ | 73.3 ± 4.4^**^ (−23%)^c^ | 84.0 ± 4.4 (−12%)^c^ | 58.7 ± 6.0^**^ (−38%)^c^
Body-weight gain/100 g intake | 18.78 ± 1.24 | 18.21 ± 0.48 (−3%) | 16.21 ± 0.63 (−14%) | 18.01 ± 1.14 (−4%) | 13.88 ± 1.3^*^ (−26%)
Intake (g/4 wk) | 507.9 ± 13.9 | 453.8 ± 15.6^*^ (−11%) | 451.1 ± 13.4^*^ (−11%) | 467.0 ± 7.1^*^ (−8%) | 421.4 ± 4.6^**^ (−17%)
P balance
Fecal (mg/d) | 23.8 ± 2.9 | 30.6 ± 3.7 (+29%) | 32.4 ± 2.3^*^ (+36%) | 45.2 ± 6.2^*^ (+90%) | 47.5 ± 3.9^**^ (+100%)
Urinary (mg/d) | 4.2 ± 0.4 | 56.5 ± 5.8^**^ (+1,245%) | 102.1 ± 9.0^**^ (+2,331%) | 179.4 ± 0.1^**^ (+4,171%) | 274.9 ± 15.6^**^ (+6,445%)
Net absorption (mg/d) | 28.0 ± 2.2 | 60.2 ± 4.8^**^ (+115%) | 99.0 ± 6.8^**^ (+254%) | 137.6 ± 7.1^**^ (+391%) | 150.1 ± 12.3^**^ (+436%)
Balance (mg/d) | 23.8 ± 2.3 | 3.7 ± 5.0^**^ (−4%) | −3.1 ± 12.1 (−113%) | −41.9 ± 7.1^**^ (−276%) | −124.8 ± 21.3^**^ (−624%)
Ca balance
Urinary (mg/d) | 0.53 ± 0.04 | 0.23 ± 0.02^**^ (−57%) | 0.17 ± 0.01^**^ (−68%) | 0.10 ± 0.00^**^ (−81%) | 0.09 ± 0.02^**^ (−83%)
Net absorption (mg/d) | 34.9 ± 5.7 | 31.5 ± 7.1 (−10%) | 28.7 ± 7.4 (−18%) | 23.3 ± 8.5 (−33%) | 4.7 ± 6.6^**^ (−87%)
Balance (mg/d) | 34.3 ± 5.7 | 31.3 ± 7.1 (−9%) | 28.5 ± 7.4 (−17%) | 23.2 ± 8.5 (−32%) | 4.7 ± 6.6^**^ (−86%)
Serum chemistry
PTH (pg/mL) | 7.82 ± 3.81 | 33.76 ± 11.43 (+332%) | 32.53 ± 19.48 (+316%) | 25.06 ± 10.35 (+220%) | 75.12 ± 0.28^**^ (+861%)
1,25(OH)_2_D_3_ (pg/mL) | 65.4 ± 4.7 | 102.6 ± 25.9 (+57%) | 115.8 ± 12.4^**^ (+77%) | 124.9 ± 51.4 (+91%) | 112.3 ± 19.0 (+72%)

a Tani et al. (2007).

b Mean ± SEM for n = 6 per group.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from the referent group at p < 0.05, based on analyses performed by the study authors.

** p < 0.01.

1,25(OH)_2_D3 = 1,25-dihydroxy-vitamin D_3_; Ca = calcium; KH_2_PO_4_ = monopotassium phosphate; P = phosphorus; PTH = parathyroid hormone; SEM = standard error of the mean.

Table B-8 Significant Effects in Male Sprague Dawley Rats Administered Inorganic Phosphate (as KH_2_PO_4_) in the Diet for 4 Weeks^a^

Parameter (units) | Dose in mg P/kg-d (% P in diet)
Parameter (units) | 530 (0.6% P in diet; referent) | 1,100 (1.2% P in diet)
Body weight (g) | 352 ± 7.5^b^ | 345 ± 8.0 (−2%) ^c^
NEFA (mEq/L) | 0.47 ± 0.03 | 0.34 ± 0.02^*^ (−28%)
PTH (pg/mL) | 40 ± 12.6 | 256.4 ± 75.7^*^ (+541%)
FGF-23 (pg/mL) | 231 ± 47.6 | 408 ± 82.6 (+77%)
BUN (mg/dL) | 12.8 ± 0.5 | 16.9 ± 1.6^*^ (+32%)

a Abuduli et al. (2016).

b Mean ± SE for six animals/group.

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from referent group at p < 0.05 based on analyses performed by the study authors.

BUN = blood urea nitrogen; FGF-23 = fibroblast growth factor-23; KH_2_PO_4_ = monopotassium phosphate; NEFA = nonesterified fatty acids; P = phosphorus; PTH = parathyroid hormone; SE = standard error.

Table B-9 Significant Effects in Birmingham-Wistar Rats Administered Inorganic Phosphate as Na_4_P_2_O_7_ or Na_2_HPO_4_ in the Diet for 16 Weeks^a^

Parameter (units) | Percent in Diet
Parameter (units) | 0.5% (referent) | 1% (as Na_4_P_2_O_7_) | 2.5% (as Na_4_P_2_O_7_) | 5% (as Na_4_P_2_O_7_) | 5% (as Na_2_HPO_4_)
Males
Dose (mg P/kg-d)^b^ | 280 | 396 (estimated) | 570 (estimated) | 860 | 840
Body-weight gain (g) | 210 ± 20^c^ | 245 ± 16 (+17%)^d^ | 229 ± 15 (+9%)^d^ | 187 ± 15 (−11%)^d^ | 234 ± 14 (+11%)^d^
Food consumption (g) | 1,309 ± 28 | 1,359 ± 27 (+4%) | 1,305 ± 24 (+0%) | 1,213 ± 48 (−7%) | 1,363 ± 18 (+4%)
RBCs (millions/mm^3^) | 7.51 ± 0.20 | 7.95 ± 0.25 (+6%) | 7.75 ± 0.17 (+3%) | 7.67 ± 0.18 (+2%) | 8.25 ± 0.31 (+10%)
Hb (g/100 mL) | 13.1 ± 0.17 | 12.8 ± 0.24 (−2%) | 12.4 ± 0.21^*^ (−5%) | 12.5 ± 0.25 (−5%) | 13.9 ± 0.29^*^ (+6%)
Specific gravity | 1.06 ± 0.003 | 1.05 ± 0.005 (−1%) | 1.04 ± 0.006^*^ (−2%) | 1.04 ± 0.005^*^ (−2%) | 1.05 ± 0.002^**^ (−1%)
Relative organ weights (mg/100 g live weight)
Heart | 244 ± 4 | 255 ± 6 (+5%) | 251 ± 77 (+3%) | 295 ± 19^*^ (+21%) | 256 ± 7 (+5%)
Stomach | 378 ± 12 | 365 ± 15 (−3%) | 388 ± 12 (+3%) | 608 ± 39^**^ (+61%) | 407 ± 14 (+8%)
Intestines | 2,229 ± 112 | 2,108 ± 111 (−5%) | 1,964 ± 83 (−12%) | 2,716 ± 239 (+22%) | 1,940 ± 99 (−13%)
Kidneys | 634 ± 21 | 598 ± 17 (−6%) | 648 ± 24 (+2%) | 769 ± 34^*^ (+21%) | 741 ± 15^**^ (+17%)
Testes | 962 ± 42 | 900 ± 29 (−6%) | 905 ± 42 (−6%) | 1,233 ± 79^*^ (+28%) | 1,005 ± 37 (+4%)
Gross pathology
Pale, pitted; kidneys | 0/10^d^ (0%)^d^ | 0/10^d^ (0%)^d^ | 0/10^d^ (0%)^d^ | 6/10^e,^ ^f^ (60%)^d^ | 6/10^e,^ ^f^ (60%)^d^
Calcification; kidneys | 0/10 (0%) | 0/10 (0%) | 0/10 (0%) | 5/10^f^ (50%) | 6/10^f^ (60%)
Hypertrophy; stomach | 0/10 (0%) | 0/10 (0%) | 0/10 (0%) | 4/10 (40%) | 0/10 (0%)
Kidney concentration test
Males | 1.0622 ± 0.0026 | 1.0547 ± 0.0047 | 1.0429 ± 0.0061^*^ | 1.0432 ± 0.0051^*^ | 1.0488 ± 0.0018^**^
Females
Dose (mg P/kg-d) ^b^ | 350 | 500 (estimated) | 725 (estimated) | 1,100 | 1,000
Body-weight gain (g) | 137 ± 7 | 129 ± 6 (−6%) | 129 ± 7 (−6%) | 114 ± 7^*^ (−17%) | 140 ± 8 (+2%)
Food consumption (g) | 1,184 ± 28 | 1,110 ± 28 (−6%) | 1,116 ± 16 (−6%) | 1,055 ± 26 (−11%) | 1,168 ± 23 (−1%)
RBCs (millions/mm^3^) | 7.30 ± 0.18 | 7.21 ± 0.15 (−1%) | 7.00 ± 0.19 (−4%) | 6.91 ± 0.53 (−5%) | 7.92 ± 0.13^*^ (+8%)
Hb (g/100 mL) | 12.4 ± 0.51 | 12.0 ± 0.46 (−3%) | 12.9 ± 0.23 (+4%) | 12.1 ± 0.36 (−2%) | 13.2 ± 0.54^*^ (+6%)
Specific gravity | 1.06 ± 0.002 | 1.06 ± 0.003 (0%) | 1.06 ± 0.002 (0%) | 1.04 ± 0.001^**^ (−1%) | 1.05 ± 0.003^*^ (−1%)
Relative organ weights (mg/100 g live weight)
Heart | 278 ± 4 | 273 ± 5 (−2%) | 295 ± 10 (+6%) | 311 ± 9^*^ (+12%) | 285 ± 9 (+3%)
Stomach | 451 ± 16 | 459 ± 15 (+2%) | 506 ± 22 (+12%) | 721 ± 63^**^ (+60%) | 486 ± 23 (+8%)
Intestines | 2,521 ± 73 | 2,928 ± 149 (+16%) | 2,626 ± 85 (+4%) | 3,203 ± 149^**^ (+27%) | 2,696 ± 103 (+7%)
Kidneys | 601 ± 12 | 629 ± 21 (+5%) | 743 ± 24^**^ (+24%) | 893 ± 42^**^ (+49%) | 838 ± 35^**^ (+39%)
Gross pathology
Pale, pitted; kidneys | 0/10 (0%) | 0/10 (0%) | 2/10 (20%) | 5/10^f^ (50%) | 7/10^f^ (70%)
Calcification; kidneys | 0/10 (0%) | 0/10 (0%) | 2/10 (20%) | 5/10^f^ (50%) | 5/10^f^ (50%)
Hypertrophy; stomach | 0/10 (0%) | 0/10 (0%) | 3/10 (30%) | 6/10^f^ (60%) | 0/10 (0%)
Kidney concentration test
Females | 1.0592 ± 0.0024 | 1.0628 ± 0.0026 | 1.0561 ± 0.0015 | 1.0445 ± 0.0014^**^ | 1.0513 ± 0.0025^*^
Combined sexes
P excretion; 3 wk (%) | 11.4 ± 0.18 | NR | NR | 82.5 ± 3.12^f^ (+71%) | NR
P excretion; 8 wk (%) | NR | NR | NR | 74.2 ± 3.03 | 75.2 ± 0.93
Histopathology
Renal damage | 5/20 (25%) | 19/20^f^ (95%) | 20/20 (100%) | 20/20^f^ (100%) | 20/2 (100%)
Cortical atrophy | 3/20 (15%) | 12/20^f^ (60%) | 12/20^f^ (60%) | 3/20 (15%) | 3/20 (15%)
Cortical hyaline degeneration | 2/20 (10%) | 11/20^f^ (55%) | 11/20^f^ (55%) | 4/20 (20%) | 2/20 (10%)
Medullary calcification | 0/20 (0%) | 1/20 (5%) | 6/20^f^ (30%) | 14/20^f^ (70%) | 15/20^f^ (75%)
Medullary necrosis | 0/20 (0%) | 1/20 (5%) | 2/20 (10%) | 12/20^f^ (60%) | 13/20^f^ (65%)
Tubular casts | 1/20 (5%) | 0/20 (0%) | 6/20 (30%) | 11/20^f^ (55%) | 11/20^f^ (55%)
Hemorrhages and exudate | 1/20 (5%) | 9/20^f^ (45%) | 10/20^f^ (50%) | 12/20^f^ (60%) | 12/20^f^ (60%)
Chronic inflammatory changes | 0/20 (0%) | 0/20 (0%) | 1/20 (5%) | 14/20^f^ (70%) | 14/20^f^ (70%)

a Datta et al. (1962).

b P content of the diet was not reported by Datta et al. (1962) for the 1 and 2.5% dose groups for either males or females. However, doses can be reasonably estimated in units of mg P/kg-day for these groups. For males, the inclusion of Na_4_P_2_O_7_ in the diet at 5% (860 mg P/kg-day) corresponds to an increase of 580 mg P/kg-day above the referent dose (0.5%, 280 mg P/kg-day). Assuming linearity, this amount was scaled for the 1 and 2.5% dose groups (116 and 290 mg P/kg-day, respectively) and added to the referent dose to generate reasonably estimated doses in units of mg P/kg-day. Thus, the inclusion of Na_4_P_2_O_7_ in the diet at 1 and 2.5% correspond to estimated doses of 396 and 570 mg P/kg-day, respectively, in males. For females, the inclusion of Na_4_P_2_O_7_ in the diet at 5% (1,100 mg P/kg-d) corresponds to an increase of 750 mg P/kg-day above the referent dose (0.5%, 350 mg P/kg-day). Assuming linearity, this amount was scaled for the 1 and 2.5% dose groups (150 and 375 mg P/kg-day, respectively) and added to the referent dose to generate reasonably estimated doses in units of mg P/kg-day. Thus, the inclusion of Na_4_P_2_O_7_ in the diet at 1 and 2.5% correspond to estimated doses of 500 and 725 mg P/kg-day, respectively, in females.

c Mean ± SE.

d Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

e Number affected/number examined (% incidence).

f Significantly different from referent group at p < 0.05, based on two-sided t-test (continuous data) or Fisher’s exact test (incidence data) performed for this review

* Significantly different from referent group at p < 0.05, based on analyses performed by the study authors.

** p < 0.01.

Hb = hemoglobin; Na_2_HPO_4_ = disodium phosphate; Na_4_P_2_O_7_ = sodium pyrophosphate; NR = not reported; P = phosphorus; RBC = red blood cell; SE = standard error.

Table B-10 Significant Effects in Male Wistar Rats Administered Inorganic Phosphate (as K_2_HPO_4_ or [NaPO_3_]_6_) in the Diet for 150 Days^a^

Parameter (units) | Dose in mg P/kg-d (% P in diet)
Parameter (units) | 380 (0.43% P in diet as K_2_HPO_4_ referent) | 1,100 (1.3% P in diet as K_2_HPO_4_) | 400 (0.46% P in diet as [NaPO_3_]_6_; referent) | 1,100 (1.2% P in diet as [NaPO_3_]_6_)
Body-weight gain (g) | 385 ± 11^b^ | 432 ± 9^**^ (+12%)^c^ | 403 ± 9^b^ | 376 ± 9 (−7%)^c^
Relative kidney weight (g/100 g body weight) | 0.71 ± 0.03 | 0.73 ± 0.04 (+3%) | 0.68 ± 0.03 | 0.73 ± 0.04 (+7%)
Relative testes weight (g/100 g body weight) | 0.79 ± 0.03 | 0.75 ± 0.19 (−5%) | 0.72 ± 0.02 | 0.80 ± 0.01^**^ (+11%)

a Dymsza et al. (1959).

b Mean ± measure of variance (not specified).

c Value in parentheses is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significant difference between groups administered the same compound (high K_2_HPO_4_ vs. low K_2_HPO_4_ or high [NaPO_3_]_6_ vs. low [NaPO_3_]_6_) at p ≤ 0.05, based on analyses performed by the study authors.

** p ≤ 0.01.

K_2_HPO_4_ = dipotassium phosphate; [NaPO_3_]_6_ = sodium hexametaphosphate; P = phosphorus.