# APPENDIX A LITERATURE SCREENING RESULTS

Figure A-1 Literature Screening Results: Human Studies

Literature Screening Results Human Studies

Figure A-2 Literature Screening Results: Animal Studies

Literature Screening Results Animal Studies