# PREFACE

This assessment titled Provisional Peer-Reviewed Toxicity Values for Perfluorobutane Sulfonic Acid and Related Compound Potassium Perfluorobutane Sulfonate is a toxicity assessment developed by the U.S. EPA’s Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA).

A Provisional Peer-Reviewed Toxicity Value (PPRTV) is defined as a toxicity value derived for use in the Superfund Program. This assessment for perfluorobutane sulfonic acid (PFBS) updates and replaces the 2014 PPRTV assessment for PFBS. Currently available PPRTV assessments can be accessed on the U.S. Environmental Protection Agency’s (U.S. EPA’s) PPRTV website at https://www.epa.gov/pprtv. Questions regarding nomination of chemicals for update can be sent to the appropriate U.S. EPA Superfund and Technology Liaison (https://www.epa.gov/research/fact-sheets-regional-science). This assessment is also available for use across multiple U.S. EPA program and regional offices, other federal agencies, states, tribes, external stakeholders, and other entities as needed as a Human Health Toxicity Value Assessment.

The perfluorobutane sulfonic acid (PFBS) toxicity assessment is one of the key goals of the Agency’s PFAS Action Plan (https://www.epa.gov/pfas/epas-pfas-action-plan) (U.S. EPA, 2019) and provides qualitative and quantitative toxicity information that can be used along with exposure information and other important considerations to assess potential health risks to determine if, and when, it is appropriate to take action to address this chemical.

The PFBS human health toxicity values presented in this assessment were developed based on the best available science. The assessment provides high-quality evaluations and conclusions drawn from publicly available information on the toxicity of PFBS. This assessment is not a regulation; rather, it provides a critical part of the scientific foundation for risk assessment decision making. The PFBS assessment provides toxicity values and information about the adverse effects of the chemical and the evidence on which the value is based, including the strengths and limitations of the data. All users, including risk assessors and risk managers, are advised to review the information, including potential uncertainties, provided in this document to ensure that the assessment is appropriate for the circumstances (e.g., exposure pathways, concentrations, presence of sensitive subpopulations) in question and the risk management decisions that would be supported by the risk assessment.

The PFBS toxicity assessment underwent a rigorous development and review process, as described below.

[underlined: Overview of major steps in the PFBS assessment development and review process]

- Draft assessment development
- Review by U.S. EPA program and regional offices (i.e., Intra-agency review)
- Review by other federal agencies (i.e., interagency review)
- External letter peer review
- Public comment period
- Second external letter peer review
- Intra-agency and interagency review

This assessment was provided for review to scientists in U.S. EPA’s program and regional offices prior to external peer review and after external peer review. Comments were submitted by:

- Office of the Administrator/Office of Children’s Health Protection
- Office of the Administrator/Office of Policy
- Office of Chemical Safety and Pollution Prevention
- Office of Land and Emergency Management
- Office of Research and Development
- Office of Water
- Region 2, New York, NY
- Region 3, Boston, MA
- Region 4, Atlanta, GA
- Region 5, Chicago, IL
- Region 8, Denver, CO

This assessment was provided for review to other federal agencies prior to external peer review and after external peer review. Representatives from federal agencies and from the Environmental Council of the States (ECOS) were briefed during the assessment scoping and draft development process on March 9, 2018; May 2, 2018; and August 27, 2018After public comment, interagency review was conducted by the Office of Management and Budget’s PFAS Technical Working Group (TWG), an interagency group composed of career staff chief scientists or their equivalents from across the Executive Branch. Comments on this assessment were submitted by a subset of TWG representatives, namely:

- Department of Defense
- Department of Health and Human Services
  - Agency for Toxic Substances and Disease Registry
  - Food and Drug Administration
  - National Institute of Environmental Health Sciences/National Toxicology Program
  - National Institute of Occupational Safety and Health
- Executive Office of the President
  - Office of Management and Budget
- National Aeronautics and Space Administration

This assessment was peer reviewed by independent, expert scientists external to U.S. EPA before and after the public comment period. The reports of the two external peer reviews and responses to comments on the U.S. EPA’s draft Human Health Toxicity Values for PFBS, dated November 2018 and October 2020, are available at https://www.epa.gov/pfas/learn-about-human-health-toxicity-assessment-pfbs. Comments from external peer review were submitted by:

- Karen Chou, PhD
  Dale Hattis, PhD
  Lisa M. Kamendulis, PhD
  Angela M. Leung, MD
  Angela L. Slitt, PhD
  David Alan Warren, MPH, PhD
  R. Thomas Zoeller, PhD

This assessment was released for public comment from November 21, 2018 to January 22, 2019. The public comments are available on Regulations.gov in the Docket ID No. EPA-HQ-OW-2018-0614.