# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGERS

- Jason C. Lambert, PhD, DABT
  Elizabeth Oesterling Owens, PhD

## CONTRIBUTORS

- Michelle Angrish, PhD
  Xabier Arzuaga, PhD
  Johanna Congleton, PhD
  Ingrid Druwe, PhD
  J. Allen Davis, MS
  Kelly Garcia, BS
  Carolyn Gigot, BA
  Andrew Greenhalgh, BS
  Joshua Harrill, PhD
  Belinda Hawkins, PhD, DABT
  Ryan Jones, MSLS
  Andrew Kraft, PhD
  Yu-Sheng Lin, PhD
  April Luke, PhD
  Elizabeth Radke, PhD
  Paul Schlosser, PhD
  Michele Taylor, PhD
  Samuel Thacker, BA
  Andre Weaver, PhD
  Jacqueline Weinberger, BS
  Amina Wilkins, MPH
  Michael Wright, ScD
  Q. Jay Zhao, PhD, MPH, DABT

## DRAFT DOCUMENT PREPARED BY

U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)

## EXECUTIVE DIRECTION

Wayne Cascio, MD, FACC | CPHEA Center Director
V. Kay Holt | CPHEA Deputy Center Director
Samantha Jones, PhD | CPHEA Associate Director
Emma Lavoie, PhD | CPHEA Senior Advisor
Tina Bahadori, ScD | NCEA Center Director (previous Exec. Direction)
Mary Ross, PhD | NCEA Deputy Center Director (previous Exec. Direction)

## PRIMARY INTERNAL REVIEWERS

- David Bussard
  Kristina Thayer, PhD
  Scott Wesselkamper, PhD