# 6.0 DERIVATION OF VALUES

The hazard and dose-response database for PFBS and the potassium salt is primarily associated with the oral route of exposure. There are a limited number of dermal studies (see Table 5) and no known inhalation studies. There are no known studies evaluating potential cancer effects of PFBS. Therefore, only noncancer reference values are derived in this assessment for the oral route.

## 6.1 DERIVATION OF ORAL REFERENCE DOSES

The hazards of potential concern for oral PFBS exposure include thyroid, developmental, and kidney effects. Overall, the evidence supports a hazard for thyroid, developmental, and kidney effects based on the evidence from animal studies. The limited evidence for thyroid or renal effects in human studies is equivocal, and no studies evaluating developmental effects following PFBS exposure in humans were available. Thus, data in humans were not considered further, and the available animal studies that evaluated these effects are considered in the derivation of oral RfDs.

### 6.1.1 Derivation of the Subchronic Oral Reference Dose

#### 6.1.1.1 Estimation of Points of Departure

Effects in the thyroid were considered when determining potential PODs for deriving a subchronic RfD. Similar patterns of decreases in total T_3_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/), total T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/), and free T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/) were observed in PFBS-exposed pregnant mice, nonpregnant adult female rats, adult male rats, and gestationally exposed female mouse offspring (NTP, 2019; Feng et al., 2017). These decreases were significant (~20% in dams and ~50% in offspring), were shown to persist at least 60 days after gestational exposure in offspring, and they exhibited a clear dose dependence in both studies. Reflex increases in TSH in response to decreased T_4_ or T_3_ were not observed in male or female rats following 28 days of exposure (NTP, 2019). Such an increase in TSH was observed in pregnant mice (measured at GD 20) and their corresponding female offspring, at PND 30 only, with an irregular dose-response or time course (Feng et al., 2017). This pattern of decreased thyroid hormone without a concomitant increase in TSH is consistent with a human clinical condition referred to as “hypothyroxinemia” (Negro et al., 2011). Importantly, milder forms of thyroid perturbation are up to 10 times more prevalent in human populations than overt gestational hypothyroidism (Korevaar et al., 2016; Stagnaro-Green et al., 2011). Hypothyroxinemia has been associated with impairments in neurodevelopment and/or cognition later in life (Thompson et al., 2018; Min et al., 2016). Because the single available study in humans had severe limitations hindering the interpretation of the relationship between PFBS exposure and thyroid hormone alterations, at this time the available evidence in humans is not able to inform the potential for thyroid effects in humans. This hypothyroxinemia, rather than overt or subclinical hypothyroidism, is further supported by the lack of effect on thyroid weight or tissue architecture in rats after 28 days of PFBS exposure (NTP, 2019).

Developmental effects were considered in determining potential PODs for derivation of a subchronic RfD. Specifically, in Feng et al. (2017), developmental delays or abnormalities in growth (i.e., BW and eye opening), reproductive organs (i.e., ovaries, uterus, and vaginal opening), and reproductive cycling (i.e., first estrous and prolongation of diestrus) were observed in mouse offspring. These effects were observed in mice from litters in which thyroid hormone deficiency occurred at PND 1 and then sustained through pubertal and adult periods (i.e., PNDs 30 and 60, respectively). These interrelated developmental effects in mice (i.e., delays and hormonal changes) are coherent with effects on the thyroid and presumed to be directly relevant to similar processes in humans; however, studies evaluating these outcomes in humans are not available.

Effects in the kidney were considered in determining potential PODs for deriving a subchronic RfD. Lieder et al. (2009a) reported mild to moderate hyperplasia in the kidneys of male and female rats following subchronic-duration exposure to PFBS, and Lieder et al. (2009b) found the same effects in the P_0_- and F_1_-generation animals in their reproductive toxicity study. Other studies evaluating effects in the kidney were of shorter duration and thus less suitable as a candidate principal study. Additional histopathological alterations accompanied the hyperplasia observed in the kidney, including papillary edema and inflammatory changes, specifically increases in chronic pyelonephritis, tubular basophilia, and mononuclear cell infiltration (Lieder et al., 2009a; Lieder et al., 2009b). Across the reported kidney histopathological effects following PFBS exposure, female rats were generally more sensitive than males.

Selected data sets from studies with multiple exposure levels for thyroid, developmental, and kidney effects were modeled using the U.S. EPA’s Benchmark Dose Software (BMDS) Version 2.7. Consistent with the U.S. EPA’s Benchmark Dose Technical Guidance Document (U.S. EPA, 2012), the BMD and 95% lower confidence limit on the BMD (BMDL) were estimated using a benchmark response (BMR) to represent a minimal, biologically significant level of change. Based on BMD guidance, in the absence of information regarding the level of change that is considered biologically significant, a BMR of 1 SD from the control mean for continuous data or a BMR of 10% extra risk for dichotomous data is used to estimate the BMD and BMDL, and to facilitate a consistent basis of comparison across endpoints, studies, and assessments. For some types of effects (e.g., frank effects, developmental effects), biological considerations may warrant the use of a BMR of 0.5 SD or lower.

For effects in developing offspring, including thyroid hormone changes, a BMR of 0.5 SD change from the control mean is used for continuous data to account for effects occurring in a sensitive life stage. A 1 SD BMR is also presented as the basis for model comparison as directed in the U.S. EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012).

For thyroid hormone effects in offspring, a biological level of concern was considered in the identification of a BMR. Multiple lines of evidence regarding the degree of thyroid hormone disruption and developmental outcomes in offspring were evaluated. During developmental life stages, such as gestational/fetal and postnatal/early newborn, thyroid hormones are critical in many physiological processes associated with somatic growth and maturation and with life functions like thermogenesis, pulmonary gas exchange, and cardiac development (Sferruzzi-Perri et al., 2013; Hillman et al., 2012). Further, thyroid hormones are critically important in early neurodevelopment because they directly influence neurogenesis, synaptogenesis, and myelination (Rovet, 2014; Puig-Domingo and Vila, 2013; Stenzel and Huttner, 2013; Patel et al., 2011). Note that evidence from human epidemiological studies examining the association between thyroid hormone economy in pregnant mothers and neurodevelopment in their offspring is inconsistent. Several human epidemiologic studies have demonstrated key relationships between decreased levels of thyroid hormones such as FT_4_ in a pregnant woman and in utero and early postnatal life neurodevelopmental status. For example, children born euthyroid but who were exposed to thyroid hormone insufficiency in utero (e.g., ≤10th percentile free T_4_), present with cognitive impairments (e.g., decreased intelligence quotient [IQ], increased risk of expressive language) and/or concomitant abnormalities in brain imaging (Levie et al., 2018; Korevaar et al., 2016; Henrichs et al., 2010; Lavado-Autric et al., 2003; Mirabella et al., 2000). Maternal hypothyroxinemia was also associated with adverse motor function and teacher-reported problems of behavior in offspring at 5 years of age (Andersen et al., 2018). Other human epidemiologic studies have not reported significant associations between thyroid hormone status during pregnancy and neurodevelopmental outcomes in offspring. For example, there was no statistically significant association between thyroid status and IQ decrements or neuropsychological parameters in children born to mothers screened and diagnosed with subclinical hypothyroidism (Hales et al., 2018; Lazarus et al., 2012) or mothers undergoing treatment for hypothyroxinemia during gestation (Casey et al., 2017). In these studies, the timing of maternal hypothyroxinemia during pregnancy may be a critical consideration for developmental health outcomes in offspring. Studies have observed a relationship between low free T_4_ levels in women at 12 weeks gestation, but not 32 weeks gestation, and impaired psychomotor development in their offspring (Kooistra et al., 2006; Pop et al., 2003). In addition, differences in the type of maternal disruption of thyroid homeostasis may affect the interpretation of the human epidemiologic study results. Specifically, aside from overt primary hypothyroidism, there are two primary subcategories of hypothyroidism: (1) subclinical hypothyroidism; and (2) hypothyroxinemia. Subclinical hypothyroidism is characterized by elevated TSH levels with normal serum T_4_ and T_3_ concentrations. In contrast, hypothyroxinemia is characterized by decreased T_4_ with normal serum concentrations of TSH and T_3_ (Alexander et al., 2017; Choksi et al., 2003). Maternal T_4_ is the primary source of thyroid hormone for a developing human fetus in the first trimester (i.e., little if any maternal T_3_ is transferred across the placenta primarily due to high levels of deiodinase 3 activity that catabolizes T_3_ to a biologically inactive form). The first trimester is also a critical window for central nervous system development (e.g., neural tube, spinal cord, medulla, pons, thalamus/hypothalamus, etc.). It therefore stands to reason that the health implications may be different for early in utero development if associated with a condition where maternal T_4_ (and T_3_) concentrations are normal (subclinical hypothyroidism) versus one involving decreased levels of T_4_ (hypothyroxinemia).

With regard to what level of decrease in thyroid hormone (e.g., T_4_) is sufficient for anatomical and/or functional alterations, particularly in neurodevelopment in fetuses or newborns, several studies have identified a range of T_4_ decrements associated with neurodevelopmental health outcomes across humans or experimental rodents. For example, neurodevelopmental and cognitive deficits have been observed in children who experienced a 25% decrease in maternal T_4_ during the second trimester in utero (Haddow et al., 1999). In other studies, mild to moderate thyroid insufficiency in pregnant women was defined as having serum T4 levels below the 10th percentile for the study population, which was associated with a 15–30% decrease relative to the corresponding median (Finken et al., 2013; Julvez et al., 2013; Román et al., 2013; Henrichs et al., 2010). In experimental animals, decreases in mean maternal T_4_ levels of ~10–17% during pregnancy and lactation have been found to elicit neurodevelopmental toxicity in rat offspring (Gilbert et al., 2016; Gilbert, 2011). With regard to a general diagnostic criterion to delineate hypothyroxinemia from other types of clinical hypothyroidism, the Controlled Antenatal Thyroid Study (CATS), conducted in a large cohort of pregnant women in Europe, resulted in the identification of a condition referred to as “isolated hypothyroxinemia” and is defined as the presence of free thyroxine (FT_4_) below the 2.5th percentile with a thyrotropin (TSH) level within the reference range (Hales et al., 2018; Lazarus et al., 2012; Negro et al., 2011). However, there is no clear or consistent biological threshold for T_4_ changes specifically associated with untoward developmental health outcomes, so a BMR of 0.5 SD was therefore identified as a default when performing BMD modeling on thyroid hormone alterations in offspring, consistent with U.S. EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012). Further, while total T_4_ (TT_4_), free T_4_ (FT_4_), and TSH dose-response data are BMD modeled (see Table 9), important biological considerations are presented in Section 6.1.1.2 that delineate TT_4_ as the key hormone metric for a developing fetus/neonate.

Significantly decreased thyroid hormone (e.g., T_4_ and T_3_) was observed in adult rats exposed twice daily to oral K^+^PFBS (NTP, 2019) for 28-days, as well as the P_0_ (maternal) mice of the Feng et al. (2017) study. No overt signs of traditional hypothyroidism such as increased TSH and increased thyroid tissue weight or histopathology were observed in either adult population. Adult rodents have a considerable reserve thyroid hormone capacity compared with the developing offspring, which depend on their supply from maternal T_4_. While there is concern over decreases in thyroid hormone (i.e., hypothyroxinemia) in developmental life stages due to critical endocrine dependency of in utero and neonatal development, the levels at which there is concern for hypothyroxinemia in euthyroid adults is unclear. Therefore, for euthyroid adult rats and mice, a biologically significant level of change was not determined for the BMR because it is unclear what magnitude of hormone perturbation would be considered adverse. Therefore, for thyroid hormone effects in adult rodents, a default BMR of 1 SD from control mean was applied. Section 6.1.1.2 presents critical distinctions between perturbations in thyroid hormone economy in adults versus developing fetus/neonates, resulting in the use of different BMRs across life stages (e.g., 1 SD for adults, 0.5 SD for newborns).

For kidney hyperplasia data from the subchronic study by Lieder et al. (2009a) and the two-generation reproductive toxicity study by Lieder et al. (2009b), a BMR of 10% extra risk was used because it is the recommended approach for dichotomous data in the absence of information on the minimally significant level of change.

#### 6.1.1.2 Approach for Animal-Human Extrapolation of Perfluorobutane Sulfonic Acid Dosimetry

As discussed in Section 1.3, toxicokinetic data exists for PFBS in relevant animal species (i.e., rats and mice) and humans, such that a data-informed adjustment approach for estimating the dosimetric adjustment factor (DAF) can be used. In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b), the U.S. EPA endorses a hierarchy of approaches to derive human equivalent oral exposures using data from laboratory animal species, with the preferred approach being physiologically based toxicokinetic modeling. Other approaches might include using chemical-specific information, without a complete physiologically based toxicokinetic model. In the absence of chemical-specific models or data to inform the derivation of human equivalent oral exposures, the U.S. EPA endorses BW^3/4^ as a default to extrapolate toxicologically equivalent doses of orally administered agents from all laboratory animals to humans for the purpose of deriving an RfD under certain exposure conditions.

The U.S. EPA concluded that data for PFBS are adequate to support derivation of data-informed dosimetric adjustment. Briefly, the ratio of the clearance (CL) in humans to animals, CL_H_:CL_A_, can be used to convert an oral dose-rate in experimental animals (mg/kg-day) to a human equivalent dose rate. Assuming the exposure being evaluated is low enough to be in the linear (or first order) range of clearance, the average blood concentration (C_AVG_) that results from a given dose is calculated as:

C_A V G_ ((mg)/(mL)) = (f_abs_ × dose ( mg / kg / hr ))/(C L ( mL / kg / hr )) chemical structure

where f_abs_ is the fraction absorbed and dose is the average dose rate expressed at an hourly rate. Assuming equal toxicity given equal C_AVG_ in humans as in mice or rats, and that f_abs_ is the same in humans as animals, the equitoxic dose, human equivalent dose (HED) (i.e., the human dose that should yield the same blood concentration (C_AVG_) as the animal dose from which it is being extrapolated), is then calculated as follows:

H E D = (P O D)/((C L_A_)/(C L_H_)) = P O D × (C L_H_)/(C L_A_) chemical structure

Thus, the DAF could be calculated as simply CL_H_:CL_A_, the ratio of clearance in humans to clearance in the animal from which the POD is obtained. However, clearance values are not reported for humans in the available toxicokinetic studies for PFBS (Xu et al., 2020; Olsen et al., 2009). Because clearance is a measure of average elimination, to calculate clearance in the absence of the information, one also needs to evaluate a companion variable, the V_d_. Neither Olsen et al. (2009) nor Xu et al. (2020) reported the V_d_ for humans. However, there is evidence suggesting that V_d_ for PFBS is relatively similar across species, including rodents (e.g., 0.12–0.29 L/kg across male and female rats following 10 mg/kg i.v. dose) and monkeys (e.g., 0.21–0.25 L/kg across male and female cynomolgus macaques following 10 mg/kg i.v. dose) (Chengelis et al., 2009; Olsen et al., 2009). Therefore, it is reasonable to assume V_d_ for humans is approximately equivalent to V_d_ for animals (i.e., V_d,H_ = V_d,A_), in which case clearance and half-life are inversely related as follows:

C L ( mL / kg / hr ) = ln ( 2 ) × (1)/(t_1 / 2_ ( hr )) × V_d_ ( mL / kg ) chemical structure

Because reliable measures of half-life in humans and animals are available for PFBS, the ratio of elimination half-life in animals from which the POD is obtained to that in humans, t_1/2,A_:t_1/2,H_, can be used to calculate the DAF, and the human equivalent dose (HED) can be calculated as follows:

H E D = P O D × (t_1 / 2_A__)/(t_1 / 2_H__) chemical structure

As described in Section 1.3, two studies evaluated the elimination of human serum K^+^PFBS in human populations with previous occupational exposure (Xu et al., 2020; Olsen et al., 2009). Initial blood concentrations of PFBS in the population examined by Xu et al. (2020) are more representative of environmental exposure, and the population was larger, including 11 male and 6 female employees when compared to Olsen et al. (2009). While the estimated serum half-life of PFBS reported by Olsen et al. (2009) overlapped with that by Xu et al. (2020) (mean: 43.8 days; range: 21.9–87.6 days), there is a statistically significant difference between these two studies. As such, the two data sets will not be combined and the half-life estimated by Xu et al. (2020) is presumed to better predict human dosimetry at environmental levels. The average half-life reported by Xu et al. (2020) (mean: 43.8 days or 1,050 hours) was assigned for t½,H.

One study evaluated the elimination of serum PFBS in mice. Lau et al. (2020) reported serum terminal half-lives of 5.8 hours in male mice and 4.5 hours in female mice. Because the half-life estimates did not vary significantly between the doses (i.e., 30 and 300 mg/kg), these parameter estimates were combined. However, there was a statistically significant difference in the half-life estimates between sexes (female mice had a slightly shorter half-life [4.5 hours] compared to males [5.8 hours]), so sex-specific half-lives were assigned for t_1/2,A_ for mice.

Two studies were used to calculate serum half-life estimates for dosimetric adjustment in rats (Huang et al., 2019a; Olsen et al., 2009). A numerical average of the terminal half-lives (t_1/2,β_) measured in rats after oral and i.v. doses is identified in Olsen et al. (2009) as 4.6 hours in males and 5.7 hours in females. Olsen et al. (2009) reported sex-specific elimination differences in half-life values in rats. A numerical average of the t_1/2,β_ measured in male rats after oral and i.v. doses in Huang et al. (2019a) is 4.9 hours. In male rats, half-life values reported in Olsen et al. (2009) and Huang et al. (2019a) are consistent, thus they were averaged for use in dosimetric adjustment, resulting in a geometric mean terminal serum half-life of 4.8 hours. The terminal half-life value reported by Huang et al. (2019a) in female rats after a 4-mg/kg i.v. dose of PFBS was 0.95 hours. Huang et al. (2019a) was not able to fit the data to a two-compartment model, thus they did not report a t_1/2,β_ for rats following oral exposure. For this reason, the mean female t_1/2,β_ value from Olsen et al. (2009) was used for dosimetric adjustment.

Table 8 presents the DAFs for converting rat and mice PODs to HEDs for PFBS.

Table 8 Mouse, Rat, and Human Half-Lives and Data-Informed DAFs

Species | Sex | Animal t_1/2_ (hr) | Human t_1/2_ (hr) | DAF (t_1/2,A_/t_1/2,H_)
Mouse | Male | 5.8^a^ | 1,050^b^ | 0.0055
Mouse | Female | 4.5^c^ | 1,050^b^ | 0.0043
Rat | Male | 4.8^d^ | 1,050^b^ | 0.0046
Rat | Female | 5.7^e^ | 1,050^b^ | 0.0054

a Terminal serum half-life of combined doses for male mice from Lau et al. (2020).

b Mean serum elimination half-life for humans (combined sexes) from Xu et al. (2020).

c Terminal serum half-life of combined doses for female mice from Lau et al. (2020).

d Geometric mean of terminal serum half-lives (t_1/2,β_) measured after all oral and i.v. doses for male rats from Olsen et al. (2009) and Huang et al. (2019a).

e Mean of terminal serum half-lives (t_1/2,β_) measured after oral and i.v. doses for female rats from Olsen et al. (2009).

DAF = dosimetric adjustment factor; i.v. = intravenous; t_1/2_ = half-life.

Where modeling was feasible, the estimated BMDLs were identified as PODs (summarized in Table 9). Further details, including the modeling output and graphical results for the model selected for each endpoint, can be found in HAWC and are discussed in Appendix F. Where dose-response modeling was not feasible, NOAELs or LOAELs were identified (summarized in Table 9).

Table 9 PODs Considered for Deriving the Subchronic RfD for K^+^PFBS (CASRN 29420-49-3)

Endpoint/Reference | Species/Life Stage—Sex | POD (HED)^a^ (mg/kg-d) | Comments^‡^
Thyroid effects
Total T_4_—Feng et al. (2017) | Mouse/P_0_—female | BMDL_1SD_ = 0.093 | Adequate model fit
Free T_4_—Feng et al. (2017) | Mouse/P_0_—female | NOAEL = 0.21 | No models provided adequate statistical or visual fit to mean responses
TSH—Feng et al. (2017) | Mouse/P_0_—female | NOAEL = 0.21 | No models provided adequate statistical or visual fit to mean responses
Total T_4_ PND 1 (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate fit to the data, specifically variance
Total T_4_ PND 1 (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.095 (BMDL_1SD_ = 0.25) | Adequate model fit
Total T_4_ PND 30—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate statistical or visual fit to mean responses
Total T_4_ PND 60—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate fit to the data, specifically variance
TSH PND 30—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate statistical or visual fit to mean responses
Total T_4_—NTP (2019) | Rat—male | LOAEL = 0.29 | No models provided adequate statistical or visual fit to mean responses
Total T_4_—NTP (2019) | Rat—female | BMDL_1SD_ = 0.037 | Adequate model fit
Free T_4_—NTP (2019) | Rat—male | LOAEL = 0.34 | No models provided adequate statistical or visual fit to mean responses
Free T_4_—NTP (2019) | Rat—female | BMDL_1SD_ = 0.027 | Adequate model fit
Developmental effects
Eyes opening (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate fit to the data, specifically variance
Eyes opening (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.073 (BMDL_1SD_ = 0.16) | Adequate model fit
Vaginal opening (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.15 (BMDL_1SD_ = 0.35) | Adequate model fit
Vaginal opening (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.094 (BMDL_1SD_ = 0.22) | Adequate model fit
First estrous (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate statistical or visual fit to mean responses
First estrous (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 | No models provided adequate statistical or visual fit to mean responses
Kidney effects
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009a) | Rat—male | BMDL_10_ = 0.49 | Adequate model fit
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009a) | Rat—female | BMDL_10_ = 0.30 | Adequate model fit
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/P_0_—male | BMDL_10_ = 0.35 | Adequate model fit
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/P_0_—female | BMDL_10_ = 0.27 | Adequate model fit
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/F_1_—male | BMDL_10_ = 0.78 | Adequate model fit
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/F_1_—female | BMDL_10_ = 0.48 | Adequate model fit

a Following U.S. EPA (2011b) and U.S. EPA (2014d) guidance, animal doses from candidate principal studies were converted to HEDs by applying a DAF, where HED = dose × DAF.

b Fetal endpoints from Feng et al. (2017) were modeled alternatively using dose-group sizes based either on total number of fetuses or dams. Given that Feng et al. (2017) seems not to have used the litter as the statistical unit of analysis, it is unclear whether the study-reported standard errors pertain to litters or fetuses. Alternatively, modeling fetal endpoints using litter n or fetal n provides two modeling results that bracket the “true” variance among all fetuses in a dose group (i.e., using the fetal n will underestimate the true variance while using the litter n will overestimate the true variance). Individual animal data were requested from study authors but were unable to be obtained.

‡ BMD modeling methods and links to modeling inputs and results in HAWC are found in Appendix F. HAWC visualization: Candidate PODs for subchronic and chronic RfD (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-candidate-pods-subchronic-and-chronic-rfd/).

BMDL_0.5SD_ = benchmark dose lower confidence limit for 0.5 SD change from the control; BMDL_10_ = 10% benchmark dose lower confidence limit; BMDL_1SD_ = benchmark dose lower confidence limit for 1 SD change from the control; DAF = dosimetric adjustment factor; HAWC = Health Assessment Workspace Collaborative; HED = human equivalent dose; K^+^PFBS = potassium perfluorobutane sulfonate; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PND = postnatal day; POD = point of departure; RfD = oral reference dose; SD = standard deviation; T_4_ = thyroxine; TSH = thyroid stimulating hormone.

#### 6.1.1.3 Considerations in Selecting the Critical Effect for Deriving Oral Reference Doses

The evidence for the thyroid, developmental, and kidney effect domains support a hazard via the oral exposure route (see Table 7). However, there are qualitative and quantitative differences in the strength of evidence between these effect domains (see Table 9). PFBS-induced perturbation of the thyroid was consistently observed across two species, sexes, life stages, and exposure durations in two independent, high-confidence studies. These perturbations involved a coherent pattern of hormonal changes with similar sensitivity in the POD ranges across life stages (e.g., maternal and PND 1/newborn BMDL_05_s of 0.093 and 0.095 mg/kg-day, respectively). Developmental effects (e.g., delayed eyes opening, vaginal opening, or first estrous) were observed in mouse litters in which decrements in thyroid hormone occurred and with similar sensitivity in the ranges of POD estimates (i.e., 0.073–0.21 mg/kg-day) (Feng et al., 2017). However, these developmental effects have been reported in a single study and species (mouse). Kidney effects in adult animals (Lieder et al., 2009a; Lieder et al., 2009b) were observed in adult or developing rats across high- or medium-confidence gavage studies of various duration; however, were less sensitive at 0.27 mg/kg-day and above.

In deriving a subchronic RfD, both the Feng et al. (2017) and NTP (2019) studies were considered as potential principal studies because of the observed sensitivity of thyroid hormone decrements. However, the biological significance of hypothyroxinemia (i.e., decreased T_4_) in adult euthyroid animals, absent additional signs of overt thyroid toxicity (e.g., reflex increase in TSH and/or alterations in tissue weight or histology), is unclear; therefore, the thyroid effects from the NTP (2019) rat study were not selected as a critical effect. The gestational exposure study in mice was selected as the principal study for deriving the subchronic RfD based on thyroid effects. The gestational exposure study conducted by Feng et al. (2017) reported administration of K^+^PFBS by gavage in ICR mice (10/dose) from GDs 1 to 20. This study was of good quality (i.e., high confidence) with adequate reporting and consideration for appropriate study design, methods, and conduct (click to see risk of bias analysis (https://hawcprd.epa.gov/rob/study/100000968/) in HAWC). Feng et al. (2017) reported statistically significantly decreased total T_3_, total T_4_, and free T_4_, as well as increased TSH in dams and offspring (increased TSH PND 30 only) gestationally exposed to PFBS.

The critical effect from the Feng et al. (2017) study was decreased serum total thyroxine (T_4_) in newborn (PND 1) mice. T_4_ and T_3_ are essential for normal growth of developing offspring across animal species [for review see Forhead and Fowden (2014)]. And, previous studies have shown that exposure to other PFAS during pregnancy results in lower T_4_ and T_3_ levels in pregnant women and fetuses or neonates (Yang et al., 2016; Wang et al., 2014). The selection of total T_4_ as the critical effect is based on a number of key considerations (see below) that account for cross-species correlations in thyroid physiology and hormone dynamics particularly within the context of a developmental life stage.

A key consideration for selecting total T_4_ is that this represents the aggregate of potential thyroid endocrine signaling (i.e., free T_4_ + protein bound T_4_) at any given time. In humans, FT_4_ represents approximately 0.03% of circulating hormone, indicating that as much as 99.97% of all T_4_ is protein bound (e.g., albumin; TBG). Although T_3_ is the active hormone form in respondent somatic tissues, the formation of T_3_ is contingent upon the deiodination of free T_4_. A critical consideration in pregnant females is that T_4_, not T_3_, is the thyroid hormone that crosses the placenta of humans and rodents. Although free T_4_ might be considered a suitable measure of thyroid hormone status in nondevelopmental (e.g., adult) life stages, there are some important factors associated with maintenance of the microenvironment for developing offspring in utero that supports using total T_4_ as the critical effect. A tightly regulated transfer of maternal thyroid hormone to a fetus is paramount to proper development of multiple tissues and organ systems (e.g., nervous system), especially during the early trimesters. The placenta has transporters and deiodinases that collectively act as a gatekeeper to maintain an optimal T_4_ microenvironment in the fetal compartment (Fisher, 1997; Koopdonk-Kool et al., 1996). For example, deiodinase 3 (D3) is highly expressed in human uterus, placenta, and amniotic membrane, where it serves a critical role of regulating thyroid hormone transfer to the fetus through the deiodination of T_4_ to transcriptionally inactive reverse triiodothyronine (rT_3_) or T_3_ to inactive 3,5-diiodo-L-thyronine (T_2_). Similarly, Wasco et al. (2003) showed that D3 is highly expressed in the rodent uterus and is highly induced during pregnancy. Further, the Dio3 gene that encodes D3 has been shown to be imprinted in the mouse (Hernandez et al., 2002), suggesting a pivotal role for this specific deiodinase in the mouse as well. Indeed, the human and rodent placenta have been shown to be similarly permeable to T_4_ and T_3_ (Fisher, 1997; Calvo et al., 1992). Due to placental barrier functionality, free T_4_ levels in a pregnant dam might not be entirely representative of actual T_4_ status in a developing fetus. Further, the American Thyroid Association published a guidelines document in 2017 in which they stated: “Current uncertainty around FT_4_ estimates in pregnancy has led some to question the wisdom of relying on any FT_4_ immunoassays during pregnancy. In contrast, measurement of TT_4_ and the calculated FT_4_ index do show the expected inverse relationship with serum TSH. This finding suggests that TT_4_ measurements may be superior to immunoassay measurement of FT_4_ measurements in pregnant women” (Alexander et al., 2017). Thus, decreased total T_4_ in offspring (and dams during pregnancy/at delivery) is expected to be more representative of PFBS-mediated thyroid effects and potentially associative developmental effects.

There are some differences in HPT development and functional maturation and regulation during early life stages (e.g., timing of in utero and early postnatal thyroid development) between humans and rodents [for a comprehensive overview see Regulatory Science Associates (2019)]. Human thyroid development occurs in three phases in utero which entails initial development of the gland between Embryonic Day 10 to Gestational Week 11 (Phase I), maturation of the fetal thyroid system from Gestational Weeks 11–35 (Phase II), and further refinement of hypothalamic-pituitary-thyroid axis functionality during the latter portion of gestation up to approximately 4 weeks into the postnatal period (Phase III) (Klein et al., 1982; Fisher and Klein, 1981). Importantly, in utero development of the rodent thyroid gland occurs in the same phases and order as humans, the difference being that rodents are essentially born during Phase II, with Phase III occurring almost exclusively postnatally; whereas in humans, Phase III is well underway in utero and completes postnatally. Accordingly, rodent neurodevelopment in the early postnatal phase is analogous to the third trimester of human development in utero (Gilbert et al., 2012). Further, fetal development of rodents in utero is entirely dependent on maternal thyroid hormone until approximately GD 17–18, whereas in humans, fetal development transitions from complete reliance on maternal thyroid hormone during the first trimester (i.e., thyroid development Phase I) to a mix of fetal thyroid hormone synthesis and maternal transplacental hormone transfer beginning in the second trimester (i.e., thyroid development Phase II) through the in utero portion of Phase III (Fisher and Klein, 1981).

Within the context of early developmental life stages, there are several commonalities in HPT dynamics between humans and rodents such as similar profiles of (1) thyroid hormone binding proteins, (2) hormone functional reserve, and (3) placental deiodinase. For example, two carrier proteins—thyroid binding globulin (TBG) and transthyretin (TTR)—are primarily responsible for storage and transit of T_4_ in mammals (Rabah et al., 2019). TBG is the primary carrier of T_4_ in humans across all life stages (Savu et al., 1991). Importantly, in fetal and infant rats, TBG is also the primary carrier of T_4_ (Savu et al., 1989). As rats transition to adulthood, TTR takes over as the primary carrier of T_4_. In addition, as a relatively highly abundant carrier protein, albumin also plays a role in thyroid hormone binding and transit in humans and rodents; however, the relative affinity for binding is lower than either TBG or TTR.

Life-stage-specific differences in thyroid hormone reserve capacity between adults and neonates have been noted. On average, intrathyroidal thyroglobulin stores in adults are on the order of months, whereas in neonates the functional reserve is approximated at less than 1 day (Gilbert and Zoeller, 2010; Savin et al., 2003; van den Hove et al., 1999). This suggests that the adult thyroid has compensatory abilities not present in early life stages, making fetal/neonatal populations particularly sensitive to perturbations in thyroid hormone economy (e.g., hypothyroxinemia). And although the timing of thyroid development can vary between species (Forhead and Fowden, 2014), the dynamic reserve capacity of T_4_ between humans and rodents near birth and in early postpartum might not be significantly different. For example, human neonates have a serum half-life of T_4_ of approximately 3 days (Vulsma et al., 1989), and thyroid tissue stores of T_4_ are estimated to be less than 1 day (van den Hove et al., 1999). Because the developing rodent thyroid does not begin producing its own hormone until late in gestation (≥GD 17), newborn rodent T_4_ levels are primarily a reflection of transplacentally translocated maternal hormone; and adult rats have been shown to have a serum T_4_ half-life of 0.5–1 day (Choksi et al., 2003). For this reason, significant differences in functional thyroid reserve capacity between human and rodent neonates are not anticipated.

Accounting for the information presented above, the subchronic RfD, based on the BMDL_0.5SD_ (HED) of 0.095 mg/kg-day for decreased serum total T_4_ in newborn (PND 1) mice, is derived as follows:

Subchronic RfD for K^+^ PFBS = BMDL_0.5 SD_ ( HED ) ÷ UFc = 0.095 mg / kg-day ÷ 100 = 0.00095 mg / kg-day = 1 × 1 0^− 3^ mg / kg-day

Table 10 summarizes the uncertainty factors for the subchronic RfD for K^+^PFBS based on effects in the thyroid.

Table 10 Uncertainty Factors for the Subchronic RfD for Thyroid Effects for K^+^PFBS (CASRN 29420-49-3)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between mice and humans following oral K^+^PFBS/PFBS exposure. Some aspects of the cross-species extrapolation of toxicokinetic and toxicodynamic processes have been accounted for by calculating an HED by applying a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b). However, some residual uncertainty remains in the relative cross-species sensitivity in toxicodynamics (e.g., thyroid signaling). Thus, in the absence of chemical-specific data to quantify these uncertainties, U.S. EPA’s guidance recommends use of a UF_A_ of 3.
UF_D_ | 3 | A UF_D_ of 3 is applied due to database deficiencies. The oral exposure database contains multiple short-term and subchronic-duration toxicity studies of laboratory animals (NTP, 2019; Bijland et al., 2011; 3M, 2010; Lieder et al., 2009a; 3M, 2001, 2000d), a two-generation reproductive toxicity study in rats (Lieder et al., 2009b), and multiple developmental toxicity studies in mice and rats (Feng et al., 2017; York, 2002). However, the observation of decreased thyroid hormone is known to be a crucial element during developmental life stages, particularly for neurodevelopment, and the database is limited by the lack of developmental neurotoxicity studies. In addition, because other health effect domains such as immunotoxicity and mammary gland development are effects of increasing concern across several members of the larger PFAS family (Grandjean, 2018; Liew et al., 2018; White et al., 2007), the lack of studies evaluating these outcomes following PFBS exposure is a limitation in the database.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for interindividual variability in the human populations because of both intrinsic (toxicokinetic, toxicodynamic, genetic, life stage, and health status) and extrinsic (life style) factors that can influence the response to dose. In the absence of chemical-specific data to quantify this variability in the toxicokinetics and toxicodynamics of K^+^PFBS/PFBS in humans, U.S. EPA recommends using a UF_H_ of 10.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a BMDL and the BMR was selected based on evidence that it represented a minimal biologically significant response level in susceptible populations such as developing offspring.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD comes from a developmental study in mice. The developmental period is recognized as a susceptible life stage in which exposure during certain time windows (e.g., gestational) is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991a).
UF_C_ | 100 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_

BMDL = benchmark dose lower confidence limit; BMR = benchmark response; DAF = dosimetric adjustment factor; HED = human equivalent dose; K^+^PFBS = potassium perfluorobutane sulfonate; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PFAS = per- and polyfluoroalkyl substances; PFBS = perfluorobutane sulfonic acid; POD = point of departure; RfD = oral reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

The data for K^+^PFBS can be used to derive a subchronic RfD for the free acid (PFBS), as K^+^PFBS is fully dissociated in water at the environmental pH range of 4–9 (NICNAS, 2005). To calculate the subchronic RfD for the free acid, the subchronic RfD for the potassium salt is adjusted to compensate for differences in MW between K^+^PFBS (338.19) and PFBS (300.10). The subchronic RfD for PFBS (free acid) is calculated as follows:

Subchronic RfD = RfD for K^+^ PFBS salt × ( MW free acid ÷ MW salt ) for PFBS ( free acid ) = 0.00095 mg / kg-day × ( 300.10 ÷ 338.19 ) = 0.00095 mg / kg-day × ( 0.89 ) = 0.00085 mg / kg-day = 9 × 1 0^− 4^ mg / kg-day

Confidence in the subchronic RfD for PFBS and K^+^PFBS for thyroid effects is medium, as explained in Table 11.

Table 11 Confidence Descriptors for the Subchronic RfD for PFBS (CASRN 375-73-5) and the Related Compound K^+^PFBS (CASRN 29420-49-3)

Confidence Categories | Designation | Discussion
Confidence in study | H | Confidence in the principal study is high because the overall study design, performance, and characterization of exposure was good. Study details and risk of bias analysis (https://hawcprd.epa.gov/rob/study/100000968/) can be found in HAWC.
Confidence in database | M | Confidence in the oral toxicity database for derivation of the candidate subchronic RfD for thyroid effects is medium because although there are multiple developmental toxicity studies in mice and rats, no studies are available that have specifically evaluated neurodevelopmental, immunological, or mammary gland effects. In addition, available toxicokinetic studies are limited (e.g., one mouse toxicokinetic study) and toxicokinetic data do not exist for PFBS at all life stages, including neonates, infants, and children. Additionally, studies are not available to estimate the relative cross-species sensitivity in toxicodynamics (e.g., thyroid signaling).
Confidence in candidate subchronic RfD | M | The overall confidence in the candidate subchronic RfD for thyroid effects is medium.

H = high; HAWC = Health Assessment Workspace Collaborative; K^+^PFBS = potassium perfluorobutane sulfonate; M = medium; PFBS = perfluorobutane sulfonic acid; RfD = oral reference dose.

The subchronic RfD is derived to be protective of all types of effects across studies and species following oral subchronic exposure and is intended to protect sensitive subpopulations and life stages.

### 6.1.2 Derivation of the Chronic Oral Reference Dose

There are no chronic studies available for PFBS and K^+^PFBS. Therefore, based on the same database and similar considerations as the subchronic RfD, the noncancer chronic RfD is derived, based on the same BMDL_0.5SD_ (HED) of 0.095 mg/kg-day for decreased serum total T_4_ in newborn (PND 1) mice (Feng et al., 2017), as follows:

Chronic RfD for K^+^ PFBS = BMDL_0.5 SD_ ( HED ) ÷ UFc = 0.095 mg / kg-day ÷ 300 = 0.00032 mg / kg-day = 3 × 1 0^− 4^ mg / kg-day

Table 12 summarizes the uncertainty factors for the chronic RfD for K^+^PFBS based on effects in the thyroid.

Table 12 Uncertainty Factors for the Chronic RfD for Thyroid for K^+^PFBS (CASRN 29420-49-3)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between mice and humans following oral K^+^PFBS/PFBS exposure. Some aspects of the cross-species extrapolation of toxicokinetic and toxicodynamic processes have been accounted for by calculating an HED by applying a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b). However, some residual uncertainty remains in the relative cross-species sensitivity in toxicodynamics (e.g., thyroid signaling). Thus, in the absence of chemical-specific data to quantify these uncertainties, U.S. EPA’s guidance recommends using a UF_A_ of 3.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for database deficiencies. The oral exposure database contains multiple short-term and subchronic-duration toxicity studies of laboratory animals (NTP, 2019; Bijland et al., 2011; Lieder et al., 2009a; 3M, 2001, 2000d), a two-generation reproductive toxicity study in rats (Lieder et al., 2009b), and multiple developmental toxicity studies in mice and rats (Feng et al., 2017; York, 2002). However, because thyroid hormone is known to be critical during developmental life stages, particularly for neurodevelopment, the database is limited by the lack of developmental neurotoxicity studies. Further, because of the lack of chronic studies, there is additional uncertainty regarding how longer-term exposures might affect hazard identification and dose-response assessment for PFBS via the oral route (e.g., potentially more sensitive effects). Lastly, because immunotoxicity and mammary gland development are effects of increasing concern across several members of the larger PFAS family (Grandjean, 2018; Liew et al., 2018; White et al., 2007), the lack of studies evaluating these outcomes following PFBS exposure is a limitation in the database.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for interindividual variability in the human populations because of both intrinsic (toxicokinetic, toxicodynamic, genetic, life stage, and health status) and extrinsic (lifestyle) factors that can influence the response to dose. In the absence of chemical-specific data to quantify this variability in the toxicokinetics and toxicodynamics of K^+^PFBS/PFBS in humans, U.S. EPA recommends using a UF_H_ of 10.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a BMDL and the BMR was selected based on evidence that it represented a minimal biologically significant response level in susceptible populations such as developing offspring.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD comes from a developmental study of mice. The developmental period is recognized as a susceptible life stage in which exposure during certain time windows (e.g., gestational) is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991b). The additional concern over potential hazards following longer term (chronic) exposures is accounted for under the UF_D_ above.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_

BMDL = benchmark dose lower confidence limit; BMR = benchmark response; DAF = dosimetric adjustment factor; HED = human equivalent dose; K^+^PFBS = potassium perfluorobutane sulfonate; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PFAS = per- and polyfluoroalkyl substances; PFBS = perfluorobutane sulfonic acid; POD = point of departure; RfD = oral reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

The data for K^+^PFBS can be used to derive a chronic RfD for the free acid (PFBS), because K^+^PFBS is fully dissociated in water at the environmental pH range of 4–9 (NICNAS, 2005). To calculate the chronic RfD for the free acid, the chronic RfD for the potassium salt is adjusted to compensate for differences in MW between K^+^PFBS (338.19) and PFBS (300.10). The chronic RfD for PFBS (free acid) for thyroid effects is the same as the value for the K^+^PFBS salt. The chronic RfD for PFBS (free acid) is calculated as follows:

Chronic RfD = RfD for K^+^ PFBS salt × ( MW free acid ÷ MW salt ) for PFBS ( free acid ) = 0.00032 mg / kg-day × ( 300.10 ÷ 338.19 ) = 0.00032 mg / kg-day × ( 0.89 ) = 0.00028 mg / kg-day = 3 × 1 0^− 4^ mg / kg-day

Confidence in the chronic RfD for PFBS and K^+^PFBS for thyroid effects is low, as explained in Table 13 below.

Table 13 Confidence Descriptors for Chronic RfD for PFBS (CASRN 375-73-5) and the Related Compound K^+^PFBS (CASRN 29420-49-3)

Confidence Categories | Designation | Discussion
Confidence in study | H | Confidence in the principal study is high because the overall study design, performance, and characterization of exposure was good. Study details and risk of bias analysis (https://hawcprd.epa.gov/rob/study/100000968/) can be found in HAWC.
Confidence in database | L | Confidence in the oral toxicity database for deriving the chronic RfD is low because, although there are multiple short-term studies and a subchronic-duration toxicity study in laboratory animals, one acceptable two-generation reproductive toxicity study in rats, and multiple developmental toxicity studies in mice and rats, the database lacks any chronic-duration exposure studies or studies that have evaluated neurodevelopmental, immunological, or mammary gland effects. In addition, available toxicokinetic studies are limited (e.g., one mouse toxicokinetic study) and toxicokinetic data do not exist for PFBS at all life stages, including neonates, infants, and children. Additionally, studies are not available to estimate the relative cross-species sensitivity in toxicodynamics (e.g., thyroid signaling).
Confidence in candidate chronic RfD | L | The overall confidence in the candidate chronic RfD for thyroid effects is low.

H = high; HAWC = Health Assessment Workspace Collaborative; K^+^PFBS = potassium perfluorobutane sulfonate; L = low; PFBS = perfluorobutane sulfonic acid; RfD = oral reference dose.

The chronic RfD is derived to be protective of all types of effects across studies and species following oral chronic exposure and is intended to protect the population as a whole, including potentially susceptible populations and life stages (U.S. EPA, 2002). This value should be applied in general population risk assessments. Decisions concerning averaging exposures over time for comparison with the RfD should consider the types of toxicological effects and specific life stages of concern. For example, fluctuations in exposure levels that result in elevated exposures during development could potentially lead to an appreciable risk, even if average levels over the full exposure duration were less than or equal to the RfD.

## 6.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

No published studies investigating the effects of subchronic- or chronic-duration inhalation toxicity of PFBS and the related compound K^+^PFBS in humans or animals have been identified.

## 6.3 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR AND DERIVATION OF CANCER RISK VALUES

No studies evaluating the carcinogenicity of PFBS or K^+^PFBS in humans or animals have been identified. In accordance with the Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005), the U.S. EPA concluded that there is “Inadequate Information to Assess Carcinogenic Potential” for PFBS and K^+^PFBS by any route of exposure. Therefore, the lack of data on the carcinogenicity of PFBS and the related compound K^+^PFBS precludes the derivation of quantitative estimates for either oral (oral slope factor) or inhalation (inhalation unit risk) exposure.

## 6.4 SUSCEPTIBLE POPULATIONS AND LIFE STAGES

Early life stages as well as pregnant women are potentially susceptible to PFBS exposure. PFBS has been detected in blood serum of nursing mothers, which might indicate a potential for lactational exposure (Glynn et al., 2012); however, information on the kinetics of lactational transfer are lacking and represents a key data gap for future research.

The available information suggests sex-specific variation in the toxicokinetics of PFBS in rodents. Studies in mice and rats generally report clearance and elimination half-lives to be faster for females than for males (see the “Toxicokinetics” section). For example, Lau et al. (2020) reports statistically significant differences in half-life between the sexes with female mice exhibiting a shorter half-life than males. Similar sex-specific variation in elimination has been reported in rats. Olsen et al. (2009) reported a statistically significant difference in the urinary clearance rates (p ≤ 0.01), with female rats (469 ± 40 mL/hour) having faster clearance rates than male rats (119 ± 34 mL/hour). Huang et al. (2019a) also reported higher clearance in female rats than in male rats given the same dose (26.0–75.5 mL/hour-kg in males, 152–259 mL/hour-kg in females). Chengelis et al. (2009) reported that the mean apparent clearance of PFBS from the serum was approximately eightfold higher for female rats (0.311 L/hour-kg) than for male rats (0.0394 L/hour-kg). Statistically significant sex-related differences in half-life or clearance were not observed between male and female monkeys (Olsen et al., 2009). Differences in the toxicokinetics in rodents could result in sex-specific differences in toxicity studies.

In vivo toxicity studies report that PFBS exposure can alter thyroid hormone levels in parental and F_1_ generation animals (see the “Thyroid Effects” section). Thyroid hormones play a critical role in coordinating complex developmental processes for various organs/systems (e.g., reproductive and nervous system), and disruption of thyroid hormone production/levels in a pregnant woman or neonate can have persistent adverse health effects for the developing offspring (Ghassabian and Trasande, 2018; Foster and Gray, 2013; Julvez et al., 2013; Román et al., 2013).

Animal studies also provide evidence that gestationally exposed females might be a susceptible subpopulation because of potential effects on female reproduction, including evidence of altered ovarian follicle development and delayed vaginal opening (see the “Reproductive Effects” section). Furthermore, gestationally exposed females also had significantly reduced BWs and delayed eye opening. These findings suggest that developmental landmarks indicative of adverse responses can be affected after PFBS exposure (see the “Offspring Growth and Early Development” section).