# 5.0 EVIDENCE INTEGRATION AND HAZARD CHARACTERIZATION

The epidemiology database of studies of PFBS exposure and health effects consists of 19 epidemiologic studies (described in 22 publications), summarized in the previous section. The experimental animal database of all repeated-dose oral toxicity studies for PFBS and the related compound K^+^PFBS includes a short-term range-finding study in rats (3M, 2000d), two 28-day studies in rats (NTP, 2019; 3M, 2001), one subchronic study in rats (Lieder et al., 2009a), one subchronic-duration lipoprotein metabolism study in mice (Bijland et al., 2011; 3M, 2010), three gestational exposure studies in mice and rats (Feng et al., 2017; York, 2003a, 2002), and a two-generation reproductive toxicity study in rats (Lieder et al., 2009b). Health outcomes evaluated across available studies included effects on the thyroid, reproductive organs and tissues, developing offspring, kidneys, liver, and lipids/lipoproteins following oral exposure to PFBS. Table 6 provides an overview of this database of potentially relevant studies and effects. This table includes only the high- and medium-confidence animal studies (a single, low-confidence animal study was not considered informative for drawing conclusions on potential health hazard[s]). The available epidemiology studies are also not included because their ability to inform conclusions about associations was limited because of the small number of studies (typically one) per outcome and poor sensitivity resulting from low exposure levels.

Following the summary of the available database in Table 6, narrative summaries describe the evidence integration judgments and the primary rationales supporting these decisions for each health effect. These narratives are supported by an evidence profile table that succinctly lays out the various factors that were judged to increase or decrease the support for a hazard. While the epidemiology studies were not influential in drawing evidence integration judgments (i.e., they were judged as equivocal for all outcomes) or the derivation of toxicity values (i.e., these studies are not discussed in the next section), the general findings are summarized below to provide context to the animal study findings and identify potential areas of future research.

Table 6 Summary of Noncancer Data for Oral Exposure to PFBS (CASRN 375-73-5) and the Related Compound K^+^PFBS (CASRN 29420-49-3)

Exposure Duration^a^ | Reference | Study Confidence | Number of Male/Female, Strain, Species, Study Type, Study Duration | Doses Tested (mg/kg-d) | Effects Observed at LOAEL | NOAEL (mg/kg-d) | LOAEL (mg/kg-d)
Short term | 3M (2000d) | Medium confidence (https://hawcprd.epa.gov/rob/study/100001452/) | 5/5, S-D rat, K^+^PFBS administered by gavage, 10 d | 0, 100, 300, 1,000 | Increased absolute and relative liver weight. | 300 | 1,000
Short term | 3M (2001) | High confidence (https://hawcprd.epa.gov/rob/study/100001409/) | 10/10, S-D rat, K^+^PFBS administered by gavage, 28 d | 0, 100, 300, 900 | Increased absolute and relative liver weight (male) and relative kidney weight (female). | 300 | 900
Short term | NTP (2019) | High confidence (https://hawcprd.epa.gov/rob/study/100001456/) | 10/10, S-D rat, PFBS administered by gavage, twice/d, 28 d | 0, 62.6, 125, 250, 500, 1,000^b^ | Decreased T_3_, free T_4_, total T_4_ in males and females. Increased relative liver weight in females and increased relative right kidney weight in males. | NDr | 62.6
Subchronic | Lieder et al. (2009a); York (2003b) | High confidence (https://hawcprd.epa.gov/rob/study/100000964/) | 10/10, S-D rat, K^+^PFBS administered by gavage, 7 d/wk, 90 d | 0, 60, 200, 600 | Increased incidence of renal hyperplasia in males and females. | 200 | 600
Subchronic | Bijland et al. (2011); 3M (2010) | Medium confidence (https://hawcprd.epa.gov/rob/study/100000970/) | 6–8/0, Apoe*3-Leiden CETP mice, K^+^PFBS in diet, 4–6 wk | 0, 30 | Alterations in lipid homeostasis (e.g., decreased hepatic lipase, triglycerides) is of uncertain biological significance. | NDr | NDr
Developmental | Feng et al. (2017) | High confidence (https://hawcprd.epa.gov/rob/study/100000968/) | 0/10, ICR mice, K^+^PFBS administered by gavage, GDs 1–20 | 0, 50, 200, 500 | Decreased T_3_, free T_4_, and total T_4_ in dams and PND 1, 30, and 60 offspring. Increased TSH in maternal and offspring (PND 30 only). Delayed eyes opening, vaginal opening, and first estrous and decreased BW in pups. | 50 | 200
Developmental | York (2003a) | High confidence (https://hawcprd.epa.gov/rob/study/100001477/) | 0/8, S-D rat, K^+^PFBS administered by gavage, GDs 6–20 | 0, 100, 300, 1,000, 2,000 | Decreased maternal feed consumption, BW gain, and gravid uterine weight. Decreased pup BW occurred at doses affecting maternal health, limiting the interpretation of the results; thus, developmental effect levels were not determined. (Limited endpoints evaluated—pilot study.) | P_0_: 1,000; F_1_: NDr | P_0_: 2,000; F_1_: NDr
Developmental | York (2002) | High confidence (https://hawcprd.epa.gov/rob/study/100001411/) | 0/25, S-D rat, K^+^PFBS administered by gavage, GDs 6–20 | 0, 100, 300, 1,000 | Decreased maternal feed consumption and BW gain. Decreased pup BW occurred at doses affecting maternal health, limiting the interpretation of the results; thus, developmental effect levels were not determined. | P_0_: 300; F_1_: NDr | P_0_: 1,000; F_1_: NDr
Reproductive | Lieder et al. (2009b); York (2003c); York (2003d); York (2003e) | High confidence (https://hawcprd.epa.gov/rob/study/100001402/) | 30/30, S-D rat, K^+^PFBS administered by gavage, two-generation reproductive study | P_0_ adults: 0, 30, 100, 300, 1,000 F_1_ adults: 0, 30, 100, 300, 1,000 | P_0_ and F_1_ adults: increased incidence of hyperplasia and focal papillary edema in the kidneys of males and females.; F_2_ pups: no dose-related effects at the highest dose tested (1,000 mg/kg-d). | P_0_, F_1_: 100; F_2_: 1,000 | P_0_, F_1_: 300; F_2_: NDr

a Duration categories are defined as follows: Acute = exposure for ≤24 hours; short term = repeated exposure for 24 hours to ≤30 days; long term (subchronic) = repeated exposure for >30 days ≤10% lifespan for humans (>30 days up to approximately 90 days in typically used laboratory animal species); chronic = repeated exposure for >10% lifespan for humans (>~90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002).

b Rats were gavaged twice daily at administered doses of 0, 31.3, 62.6, 125, 250, and 500 mg/kg in NTP (2019).

BW = body weight; GD = gestation day; NDr = not determined; ICR = Institute of Cancer Research; K^+^PFBS = potassium perfluorobutane sulfonate; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PFBS = perfluorobutane sulfonic acid; PND = postnatal day; S-D = Sprague-Dawley; T_3_ = triiodothyronine; T_4_ = thyroxine; TSH = thyroid-stimulating hormone.

## 5.1 THYROID EFFECTS

PFBS-induced perturbation of the thyroid was consistently observed across two species, sexes, life stages, and exposure durations in two independent, high-confidence studies. These perturbations involved a coherent pattern of hormonal changes. Significant changes in tissue weight or histopathology were not observed.

Similar patterns of decreases in total T_3_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/), total T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/), and free T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/) were observed in PFBS-exposed pregnant mice, nonpregnant adult female and adult male rats from a 28-day study, and gestationally exposed female mouse offspring (NTP, 2019; Feng et al., 2017). These decreases were statistically significant (~20% in dams and ~50% in offspring) and shown to persist at least 60 days after gestational exposure in offspring and exhibited dose dependence in both studies.

Development of numerous organ systems, including neuronal, reproductive, hepatic, and immune systems, is affected by altered thyroid homeostasis because adequate levels of thyroid hormones are necessary for normal growth and development in early life stages (Forhead and Fowden, 2014; Gilbert and Zoeller, 2010; Hulbert, 2000). Thus, the observed effects of PFBS exposure on thyroid hormone economy are biologically consistent with the reported delays and abnormalities in organ/system development discussed below. It is well established that the presence of sufficient thyroid hormones during the gestational and neonatal period is essential for brain development and maturation. Studies specifically evaluating the effect of PFBS on neurodevelopment were not identified, leaving uncertainty as to the potential for adverse developmental effects. Nonetheless, the coherence of these PFBS findings, in addition to the large number of xenobiotic exposure studies demonstrating associations between thyroid hormone economy and decrements in early life stage growth, development, and survival, provides support for thyroid hazard.

Taken together, the evidence in animals for thyroid effects supports a hazard. The single available study in humans did not report an association with thyroid hormones, but had severe limitations hindering its interpretation. This low-confidence (https://hawcprd.epa.gov/rob/study/100515513/) cross-sectional study was conducted in a highly selected population (i.e., women with premature ovarian insufficiency), had poor sensitivity, and methodological limitations (Zhang et al., 2018). The limited evidence for thyroid effects in human studies is equivocal. Although there are some differences in hypothalamic-pituitary-thyroid (HPT) regulation across species (e.g., serum hormone-binding proteins, hormone turnover rates, and timing of in utero thyroid development), rodents are generally considered to be a good model for evaluating the potential for thyroid effects of chemicals in humans (Zoeller et al., 2007). For more details pertaining to HPT dynamics and the similarities and differences associated with thyroid hormone economy between rodents and humans, please refer to A Literature Review of the Current State of the Science Regarding Species Differences in the Control of, and Response to, Thyroid Hormone Perturbations. Part 1: A Human Health Perspective (Regulatory Science Associates, 2019). The pattern of decreased thyroid hormones in the absence of a coordinated reflex increase in TSH and commensurate alterations in thyroid tissue weight and/or histology, observed in PFBS studies [e.g., Feng et al. (2017)], is consistent with the human clinical condition referred to as “hypothyroxinemia,” which is commonly associated with pregnancy in humans. Hypothyroxinemia has been defined as a low percentile value of FT_4_ (ranging from the 2.5th percentile to the 10th percentile of FT_4_), with a TSH level within the normal reference range (Hales et al., 2018; Alexander et al., 2017; Lazarus et al., 2012; Negro et al., 2011). Overall, based on findings in animal models considered to be informative for evaluating the potential for thyroid effects in humans, the available evidence supports a hazard, and the thyroid is considered a potential target organ for PFBS toxicity in humans.

## 5.2 DEVELOPMENTAL EFFECTS

Overt effects on birth parameters and early development have generally not been observed in either rats or mice after PFBS exposure. Specifically, the available studies do not provide evidence of effects on endpoints relating to pregnancy loss, fetal survival, or fetal morphology (Feng et al., 2017; Lieder et al., 2009a; York, 2003a, c, 2002). While one mouse study indicated pronounced decreases in female offspring BW at several ages after gestational exposure (Feng et al., 2017), several other studies either did not observe decreases in offspring BW or only detected these changes when parental BWs were similarly affected (Feng et al., 2017; Lieder et al., 2009a; York, 2003a, c, 2002).

Delays in development have been reported following gestational PFBS exposure in mice, including delayed development of the female reproductive organs (i.e., ovaries, uterus, and vaginal patency), delayed and abnormal estrous cycling (i.e., first estrous and prolongation of diestrus), and delayed eye opening (Feng et al., 2017). Age at vaginal patency and ovarian follicle counts (i.e., in F_1_ rat offspring after delivery of the F_2_ generation) were unaffected at 1,000 mg/kg-day in a two-generation reproductive toxicity study (Lieder et al., 2009a). This observed lack of effects (i.e., on vaginal patency) is inconsistent with the findings in mice. However, Feng et al. (2017) also noted changes in reproductive hormones that might be relevant to the delays in female sexual development, including a decrease in serum estradiol and increased luteinizing hormone in pubertal offspring (i.e., PND 30 [Note: progesterone was decreased at a later age, PND 60, but not PND 30]). Because the changes reported in mice by Feng et al. (2017) were observed in parallel with effects on thyroid hormone levels (discussed above), it is plausible that these developmental delays and hormonal changes could represent sequalae of reduced thyroid function, although that was not directly tested.

For the most part, developmental effects have been reported in a single study and species (mouse); however, the findings are coherent with one another as well as with the consequences of decreased thyroid hormone levels. Because of the coherence across effects on the thyroid and several interrelated developmental effects in mice (i.e., delays and hormonal changes), the evidence in animals for developmental effects supports a hazard. There is no reason to expect that the specific developmental delays observed in mice would not be directly relevant to similar processes in humans. Thus, based on findings in animals that are presumed to be relevant to humans, the available evidence supports a hazard and the developing offspring is considered a potential target for PFBS toxicity in humans. Because no studies in humans were available that investigated these endpoints, this represents an area deserving of additional research.

## 5.3 REPRODUCTIVE EFFECTS

Reproductive outcomes, including male and female fertility, pregnancy outcomes, hormone levels, markers of reproductive development, and reproductive organ weights and histopathology, have been evaluated in a number of high-confidence studies in mice (Feng et al., 2017) and rats (NTP, 2019; Lieder et al., 2009a; Lieder et al., 2009b). In addition, five low-confidence human studies evaluated potential associations between PFBS exposure and reproductive effects (Yao et al., 2019; Song et al., 2018; Zhang et al., 2018; Zhou et al., 2017a; Zhou et al., 2016).

PFBS exposure has resulted in no significant changes in male mating and fertility parameters, reproductive organ weights, or reproductive hormones. Although there were some slight, statistically significant effects on male reproductive endpoints in two rat studies [specifically, altered sperm parameters such as percentage of abnormal sperm or testicular sperm count (NTP, 2019; Lieder et al., 2009a) and delayed preputial separation at 1,000 mg/kg-day (Lieder et al., 2009a)], these findings were observed only at the highest doses and the levels of change were of questionable biological significance. No significant reproductive effects in men were noted across two human studies (Song et al., 2018; Zhou et al., 2016), although U.S. EPA noted a nonsignificant inverse association with testosterone and estradiol in male infants in one study (Yao et al., 2019).

In general, PFBS exposure in adults has also resulted in no significant alterations in female fertility or pregnancy outcomes in rats or mice (NTP, 2019; Feng et al., 2017; Lieder et al., 2009a; Lieder et al., 2009b) or in two human studies (Yao et al., 2019; Zhang et al., 2018; Zhou et al., 2017a; Zhou et al., 2016), and inconsistent changes in rodent reproductive organ weights were reported across studies regardless of duration and timing of exposure. However, changes in normal estrous cyclicity, specifically prolongation of the diestrus stage, have been reported in both nonpregnant adult rats exposed to PFBS (NTP, 2019) and adult mouse offspring exposed gestationally from GDs 1 to 20 (Feng et al., 2017). PFBS exposures in NTP (2019) began between 8 and 10 weeks of age; although the exposures might overlap with some aspects of reproductive development or changes in function during adolescence, these rats were sexually mature and thus the endpoints are considered in the context of reproductive, rather than developmental, effects. The mouse offspring in the study by Feng et al. (2017) also displayed delayed vaginal patency and histopathological markers of decreased fertility (i.e., decreased follicles and corpora lutea); however, the reproductive function of those offspring was not tested. While adult rat offspring (F_1_) in a two-generation toxicity study also exhibited variable changes in estrous cyclicity (Lieder et al., 2009b), including prolonged diestrus at 100 mg/kg-day, this effect was not observed at higher doses, limiting interpretation, and no effects on vaginal patency were observed. Female reproductive hormones can inform the potential for effects on reproductive organ development, estrous cyclicity, and fertility. Changes in serum hormones included increased testosterone after exposure of female rats as adults (NTP, 2019), increased luteinizing hormone and decreased estradiol in pubertal mice after gestational exposure (Feng et al., 2017), and decreased estradiol and progesterone when these gestationally exposed mice were assessed as adults. Overall, the pattern and timing of hormonal changes after PFBS exposure is difficult to interpret and likely incomplete. However, the hormonal alterations after gestational PFBS exposure in mice are most relevant to conclusions about female reproductive health.

Taken together, the evidence indicates that the developing reproductive system, particularly in females, might be a target for PFBS toxicity. However, the potential for reproductive effects in adults was less clear, and significant impacts on mating or fertility parameters were not observed across the available studies. Therefore, the evidence in developing animals is considered most informative to conclusions relating to potential developmental effects (see above) and the evidence for reproductive effects (i.e., in adults) is equivocal. In the three studies of potential reproductive effects in humans, no clear associations were observed, so the evidence in human studies is equivocal. Overall, based on equivocal human and animal evidence, the available evidence for reproductive effects is equivocal.

## 5.4 RENAL EFFECTS

Renal effects associated with oral exposure to PFBS have been observed in adult or developing rats across high- or medium-confidence gavage studies of various duration (NTP, 2019; Lieder et al., 2009a; Lieder et al., 2009b; 3M, 2001, 2000d).

Statistically significant increases in kidney weights have been observed in male and female rats after short-term exposure in one study (NTP, 2019), with strong dose-dependence for changes in relative weights in female rats at doses as low as 62.6 mg/kg-day. This study was likewise the only study to observe changes in serum markers of renal injury, specifically increased BUN in males at ≥250 mg/kg-day. However, while several other studies noted slight increases in weights, typically at higher PFBS doses (≥500 mg/kg-day), U.S. EPA found that these nonsignificant changes were not consistently observed across the set of available studies and no other studies reported changes in serum markers of renal injury (Lieder et al., 2009a; Lieder et al., 2009b; 3M, 2001, 2000d).

Several kidney histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-effects-kris-v3/) lesions (i.e., CPN, hydronephrosis, tubular degeneration, and tubular dilation) were unaffected by PFBS exposure in rats, although each of these endpoints was not assessed across several studies (NTP, 2019; Lieder et al., 2009a; 3M, 2000d). Mixed results were reported for mineralization and necrosis. Both of these endpoints were noted in females, but not males, after subchronic exposure to 600 mg/kg-day (Lieder et al., 2009a), whereas mineralization was unaffected in male or female rats after short-term exposure (3M, 2000d), and necrosis was unaffected in male or female rats in short-term and two-generation (in both generations) studies (NTP, 2019; Lieder et al., 2009b). Multiple markers of inflammatory changes were consistently noted in the two longest exposure duration studies, which were the only studies to report on these endpoints. Specifically, increases in chronic pyelonephritis, tubular basophilia, and mononuclear cell infiltration were observed in female, but not male, rats following subchronic exposure to 600 mg/kg-day (Lieder et al., 2009a). Similarly, increases in papillary edema and hyperplasia were observed in male and female rats after subchronic exposure to 600 mg/kg-day (Lieder et al., 2009a), and in both generations of rats in the two-generation study at ≥300 mg/kg-day (Lieder et al., 2009b), with female rats being more sensitive than males.

Overall, the evidence in animals suggests an increased sensitivity of female rats (i.e., based on histopathology and organ-weight changes). Due primarily to the consistency and coherence in renal effects observed in the subchronic study by Lieder et al. (2009a) and the reproductive toxicity study by Lieder et al. (2009b) in male and female rats, the evidence in animals supports a hazard. There is insufficient evidence in the epidemiology studies of PFBS to inform the human relevance of these findings. Taken together, the renal histopathology evidence in rodents identifies a toxicologically significant spectrum of effects that is presumed to be relevant to similar changes known to occur in humans. Renal effects (i.e., uric acid) were evaluated in one low-confidence human study, and no clear association was observed; therefore, the evidence in human studies is equivocal. Overall, based on findings in animals that are presumed to be relevant to humans, the available evidence supports a hazard and indicates the kidney as a target organ of PFBS toxicity.

## 5.5 HEPATIC EFFECTS

Hepatic effects, including organ-weight changes and histopathology associated with oral exposures to PFBS, have been observed in high- or medium-confidence studies in adult or developing rats following short-term- and subchronic-duration exposures (NTP, 2019; Lieder et al., 2009a; 3M, 2001, 2000d) and in a two-generation reproductive study in rats (Lieder et al., 2009b). Increased absolute and/or relative liver weights were consistently observed in male and female rats after short-term and multigenerational exposure (NTP, 2019; Lieder et al., 2009b; 3M, 2001, 2000d). In some studies, the magnitude of the liver-weight changes and the doses at which effects occurred differed across sexes of rat, although the pattern across studies was unclear and did not consistently indicate one sex as more sensitive. Liver histopathology, including necrosis and inflammation, was not consistently observed across PFBS studies. One possible exception is increases in hepatocellular hypertrophy in male rats observed across two studies (NTP, 2019; Lieder et al., 2009b), although female rats were unaffected in the multigenerational study and this lesion was not observed at up to 600 mg/kg-day in the subchronic study by Lieder et al. (2009a). The only study to observe changes in serum markers of liver injury was NTP (2019), at ≥250 mg/kg-day in females and ≥500 mg/kg-day in males. The biological relevance or significance of the observed liver effects is not clear. In particular, the adversity of the variable changes in liver weight and observations of cellular hypertrophy is unclear. Further, the observed lesions either occurred in only one sex of rat, were not dose dependent compared with control, and/or occurred only at the highest PFBS dose tested. Thus, the evidence in animals is equivocal. Overall, based on equivocal animal evidence and a lack of human studies, the available evidence for hepatic effects is equivocal.

## 5.6 EFFECTS ON LIPIDS OR LIPOPROTEINS

Few studies have examined the effects of PFBS on circulating or hepatic lipid or lipoprotein homeostasis. It is recognized that increased circulating levels of lipids and lipoprotein products and/or increased hepatic lipid load are clinical observations of concern in humans. However, the lack of effect on lipid dynamics in most studies of rats exposed to high oral K^+^PFBS doses for up to 90 days and the generally modest effects in transgenic mice, fed a high-fat, western-type diet renders this potential health outcome of unclear toxicological significance at this time. Thus, given the inconsistent, modest effects and the unclear biological relevance of these changes in isolation (i.e., lipids/lipoproteins were decreased, not increased) the evidence in animals is equivocal. Effects on serum lipids were evaluated in one low-confidence human study and childhood adiposity was evaluated in one medium-confidence study. Although an association was observed between increased PFBS exposure and increased total cholesterol and higher adiposity, this evidence in humans is equivocal due to lack of additional supportive evidence. Overall, based on equivocal evidence in both animal and human studies, the available evidence for effects on lipid or lipoprotein homeostasis is equivocal.

## 5.7 IMMUNE EFFECTS

Immune effects were observed in two human studies, including associations with asthma (Dong et al., 2013a) and atopic dermatitis (Chen et al., 2018). Exposure of human peripheral blood leukocytes or human promyelocytic THP-1 cells to PFBS, in culture, decreased cytokine (e.g., TNFα and IL-10) secretion following antigen challenge (Corsini et al., 2012). Because of the lack of additional evidence and some concerns about potential for residual confounding by other PFAS, the evidence in human studies is equivocal. Overall, based on equivocal evidence in human studies and a lack of animal studies, the available evidence for immune effects is equivocal.

## 5.8 CARDIOVASCULAR EFFECTS

Cardiovascular effects were observed in two human studies, including associations with cardiovascular disease in adults (Huang et al., 2018) and hypertensive disorders in pregnancy (Huang et al., 2019b). The results are compelling, but as with the evidence for immune effects, there is a lack of additional supportive evidence and some concerns about potential for confounding; thus, the evidence in human studies is equivocal. Overall, based on equivocal evidence in human studies and a lack of animal studies, the available evidence for cardiovascular effects is equivocal.

## 5.9 EVIDENCE INTEGRATION AND HAZARD CHARACTERIZATION SUMMARY

Based on the evidence integration judgments regarding the potential for PFBS exposure to cause health effects (the narrative above is summarized in Table 7), the animal studies informing the potential effects of PFBS exposure on thyroid function, renal function, and development were concluded to support a hazard. Thus, for the purposes of this assessment, the animal data supporting these outcomes were considered for use in dose-response analysis, and other data were considered no further.

Table 7 Summary of Hazard Characterization and Evidence Integration Judgments

Studies and Confidence | Factors That Increase Support for Hazard | Factors That Decrease Support for Hazard | Summary of Findings | Overall Evidence Integration Judgment and Basis
Thyroid effects
Human studies | | | | Supports a hazard (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is thyroid hormone decreases in mice and rats at ≥62.6 mg/kg-d.
- Low-confidence case-control study (Zhang et al., 2018) | - No factors noted. | - Single study of low confidence and poor sensitivity. | No association of PFBS with free T_3_, free T_4_, or thyroid stimulating hormone, but the study had poor sensitivity and other methodological limitations that hinder interpretability. | Supports a hazard (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is thyroid hormone decreases in mice and rats at ≥62.6 mg/kg-d.
Animal studies (https://hawcprd.epa.gov/summary/visual/100000045/) (all gavage) | | | | Supports a hazard (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is thyroid hormone decreases in mice and rats at ≥62.6 mg/kg-d.
[underlined: Mouse Studies:]; - High-confidence gestational (GDs 1–20) exposure study (Feng et al., 2017); [underlined: Rat Studies:]; - High-confidence short-term (28-d) toxicity study (NTP, 2019) | - Consistent thyroid hormone decreases (i.e., for total T_3_, total T_4_, and free T_4_) across two high-confidence studies of varied design. The findings were consistent across two species, sexes, life stages, and exposure durations.; - Dose-response gradients were observed for those thyroid hormones.; - Large magnitudes of effect (e.g., up to ~50% reductions in offspring serum hormones) were reported for those thyroid hormones. | - No factors noted. | Similar patterns of decreases in thyroid hormones (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-thyroid-effects/) (i.e., for total T_3_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/), total T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/), and free T_4_) were observed in PFBS-exposed pregnant mice and gestationally exposed female mouse offspring at ≥200 mg/kg-d (Feng et al., 2017) and in adult female and male rats at ≥62.6 mg/kg-d (NTP, 2019).; Increased TSH (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-tsh-effect-size-animal/) was reported in mouse dams and in pubertal (PND 30) offspring following gestational exposure (Feng et al., 2017), but no changes were noted in rats exposed as adults (NTP, 2019).; Thyroid weight and histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-thyroid-effects/) were not changed after short-term exposure in adult male or female rats (NTP, 2019). | Supports a hazard (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is thyroid hormone decreases in mice and rats at ≥62.6 mg/kg-d.
Developmental effects
Human studies | | | | Supports a hazard (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is a set of persistent developmental delays and alterations in reproductive system maturation in female mice, generally at ≥200 mg/kg-d.
No studies available to evaluate. | -- | -- | --
Animal studies (https://hawcprd.epa.gov/summary/visual/100000046/) (all gavage)
[underlined: Mouse Studies:]; - High-confidence gestational (GDs 1–20) exposure study (Feng et al., 2017); [underlined: Rat Studies:]; - Two high-confidence gestational exposure (GDs 6–20) studies: a range-finding study and a follow-up study (York, 2003c, 2002); - High-confidence two-generation study (Lieder et al., 2009b) | - Biologically consistent spectrum of developmental effects in female offspring in a high-confidence mouse study at doses not causing maternal toxicity, including pronounced and persistent effects on BW, delays in developmental milestones and sexual maturation, concordant effects on reproductive organs, and altered serum hormones.; - Concerning magnitude of effect (e.g., ~25% change in pup weight) and dose-dependence for several parameters.; - Coherence of effects with thyroid hormone insufficiency (see above).; Note: these effects were also coherent with effects on estrous cyclicity observed after short-term exposure in adult rats (NTP, 2019), but this was categorized as a reproductive effect (see below). | - Developmental effects were limited to changes in one study, sex, and species.; - A high-confidence rat study reported some inconsistent evidence, including lack of a delay in vaginal patency and lack of clear effects on estrous cyclicity or ovarian morphology, although the latter endpoint was assessed in much older animals. These potential differences across species are not explainable based on toxicokinetics alone. | In the only mouse study (Feng et al., 2017), developmental effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-developmental-effects/) and altered markers of female reproductive development or function (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-development/) were observed in female offspring after gestational PFBS exposure, including decreased BW, delayed eye opening (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-eye-opening-effect-size-animal/), delayed vaginal opening (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-vaginal-opening-effect-size-animal/), altered estrous cyclicity (including prolonged diestrus), altered reproductive hormones (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-hormone-effects2/) (e.g., decreased estradiol and progesterone), and effects on reproductive organs (e.g., weight and ovarian morphology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-female-fertility-effects/)). Most effects were observed at ≥200 mg/kg-d, with several changes noted at PND 60. Endpoints relating to fertility, pregnancy, survival, and fetal alterations (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-female-fertility-effects/) were unchanged in both rats and mice across the four available studies, although this was not tested in mouse offspring (Feng et al., 2017).; Developmental (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-developmental-effects/) BW changes in rat offspring were either unchanged (Lieder et al., 2009b) or observed only at doses causing parental toxicity (York, 2003c, 2002).; In a rat two-generation study, while some statistically significant findings were noted for markers of female reproductive development or function (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-development/), they were not dose-dependent or were of questionable biological relevance; thus, no clear changes in F_1_ offspring were noted at doses up to 1,000 mg/kg-d regarding vaginal patency (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-vaginal-opening-effect-size-animal/) or estrous cycling at comparable ages to (Feng et al., 2017), or in ovarian morphology after the F_1_ females gave birth to the F_2_ pups.
Reproductive effects
Human studies (https://hawcprd.epa.gov/summary/visual/100000051/) | | | | Equivocal (equivocal human and animal evidence).; Note: As the strongest evidence for female reproductive effects was in offspring that were gestationally exposed, these findings were considered most relevant to developmental, not reproductive, effects.
Male reproductive effects
- Low-confidence cohort study (Zhou et al., 2016); - Low-confidence cross-sectional study (Song et al., 2018); - Low-confidence cross-sectional study (Yao et al., 2019) | - No factors noted. | - Lack of clear association in studies of low confidence with poor sensitivity (i.e., due to low exposure levels, range). | No clear association between PFBS exposure and male reproductive hormones (Zhou et al., 2016) or semen parameters (Song et al., 2018) in adults. A study in newborns reported nonsignificant inverse associations between PFBS exposure and testosterone and estradiol (Yao et al., 2019).
Female reproductive effects
- Low-confidence cross-sectional study (Zhou et al., 2017a); - Low-confidence cohort study (Zhou et al., 2016); - Low-confidence cross-sectional study (Yao et al., 2019); - Low-confidence case-control study (Zhang et al., 2018) | - No factors noted. | - Lack of clear association in studies of low confidence with poor sensitivity (i.e., due to low exposure levels, range).; - Potential for reverse causation for menstrual cycle characteristics and premature ovarian insufficiency. | No clear association between PFBS exposure and female reproductive hormones (Zhou et al., 2016) or menstrual cycle characteristics (Song et al., 2018).
Animal studies (https://hawcprd.epa.gov/summary/visual/100000049/) (all gavage)
Male reproductive effects
[underlined: Rat Studies:]; - High-confidence short-term (28-d) toxicity study (NTP, 2019); - High-confidence two-generation study (Lieder et al., 2009b); - High-confidence subchronic study (Lieder et al., 2009a) | - No factors noted. | - A few small, statistically significant changes were not dose-dependent or were of questionable biological relevance.; - Lack of effects on male mating and fertility, hormones, or reproductive organs in rats. | Statistically significant effects on sperm health (NTP, 2019; Lieder et al., 2009a) and delayed preputial separation (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-development/) at 1,000 mg/kg-d (Lieder et al., 2009b) were not observed at lower doses, were within the normal range of historical controls for the laboratory, and/or were no longer significantly changed after correcting for other variables (e.g., BW).; Other relevant parameters (e.g., organ weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-organ-effects/), mating success, and so forth) were unchanged in the three studies.
Female reproductive effects
[underlined: Mouse Studies:]; - High-confidence gestational (GDs 1–20) exposure study (Feng et al., 2017); [underlined: Rat Studies:]; - High-confidence short-term (28-d) toxicity study (NTP, 2019); - High-confidence subchronic study (Lieder et al., 2009a); - High-confidence two-generation study (Lieder et al., 2009b) | - Effects on markers of female reproductive function (i.e., estrous cyclicity) were observed in high-confidence studies in rats and mice.; - Changes in reproductive serum hormones were observed in female rats (i.e., increased testosterone) and mice (e.g., decreased estradiol and progesterone). Although the pattern of change is difficult to interpret and likely incomplete, there were no conflicting data. | - Lack of similar effects on reproductive function (i.e., estrous cyclicity) in a second high-confidence rat study.; - Lack of effects on female fertility or pregnancy measures, although this was untested in prenatally exposed female mouse offspring.; - Lack of organ-weight changes in three rat studies.; Note: The lack of effects on ovarian follicles in rats did not decrease the support for hazard provided by findings in mice, as the age at endpoint assessment was not comparable. | See “Developmental effects” (above) for findings from Feng et al. (2017) and Lieder et al. (2009b).; Altered estrous cyclicity (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-development/) (including prolonged diestrus) and increased serum testosterone (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-hormone-effects2/) were observed in female rats after short-term exposure, primarily at ≥250 mg/kg-d (NTP, 2019).; Female reproductive organ weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-organ-effects/) were reduced in gestationally exposed mouse offspring (Feng et al., 2017), but were unchanged after short-term, subchronic, or two-generational exposure (NTP, 2019; Lieder et al., 2009a; Lieder et al., 2009b).
Renal effects
Human studies (https://hawcprd.epa.gov/rob/study/100001468/) | | | | Supports a hazard. (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is kidney histopathology in rats, primarily females, at ≥300 mg/kg-d.
- Low-confidence cross-sectional study (Qin et al., 2016) | - No factors noted. | - Inconsistency across subpopulations in single study.; - Single study of low confidence with concern for potential reverse causality. | Overall, there was no clear association for PFBS and uric acid. No association observed between PFBS and uric acid in the total population. Increase in uric acid with increased exposure in boys but decrease for girls (neither was statistically significant). | Supports a hazard. (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is kidney histopathology in rats, primarily females, at ≥300 mg/kg-d.
Animal studies (https://hawcprd.epa.gov/summary/visual/100000047/) (all gavage) | | | | Supports a hazard. (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is kidney histopathology in rats, primarily females, at ≥300 mg/kg-d.
[underlined: Rat Studies:]; - One high-confidence subchronic study (Lieder et al., 2009a); - Two high-confidence study (NTP, 2019;3M, 2001) and one medium-confidence (3M, 2000d) short-term (10–28 d) study; - One high-confidence two-generation study (Lieder et al., 2009b) | - Two high-confidence studies with the longest exposure durations reported consistent effects on kidney histopathology in male and female rats (females were more sensitive).; - The histopathological effects related to inflammation were largely dose-dependent and of a concerning magnitude, although primarily at high doses (300 or 600 mg/kg-d). | - Inconsistency in kidney-weight changes across studies.; - Findings are from a single laboratory and species.; Note: The general lack of effects on other pathology endpoints in the shorter term studies was not considered to decrease support for hazard, as this was not interpreted as inconsistent. | Increases in kidney weight (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-weight-effect-size-animal/) in male and female rats were observed in one short-term study at ≥ 62.6 mg/kg-d, but clear changes were not observed in the other short-term, subchronic, or two-generation rat studies.; Kidney histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-effects-kris-v3/) for some effects (i.e., CPN, hydronephrosis, tubular degeneration, and tubular dilation) was unchanged in single-study evaluations, and mixed results across studies were reported for mineralization and necrosis (NTP, 2019; Lieder et al., 2009a; Lieder et al., 2009b; 3M, 2000d).; Multiple markers potentially related to inflammation (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-histopathology-effect-size-animal/) and most notably papillary edema and hyperplasia were increased in the two longest duration studies (Lieder et al., 2009a; Lieder et al., 2009b), without contrary evidence.; Other markers of renal injury (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-effects-kris-v3/), including BUN and creatinine, were mostly unaffected across studies (NTP, 2019; Lieder et al., 2009a; Lieder et al., 2009b; 3M, 2001, 2000d), although the NTP study did observe effects on BUN in males at ≥250 mg/kg-d. | Supports a hazard. (animal evidence supports a hazard; human evidence is equivocal).; The primary basis for this judgment is kidney histopathology in rats, primarily females, at ≥300 mg/kg-d.
Hepatic effects
Human studies | | | | Equivocal (equivocal human and animal evidence).
No studies available to evaluate | – | – | – | Equivocal (equivocal human and animal evidence).
Animal studies (https://hawcprd.epa.gov/summary/visual/100000048/) (all gavage) | | | | Equivocal (equivocal human and animal evidence).
[underlined: Rat Studies:]; - One high-confidence subchronic study (Lieder et al., 2009a); - Two high-confidence studies (NTP, 2019;3M, 2001) and one medium-confidence (3M, 2000d) short-term (10–28 d) study; - One high-confidence two-generation study (Lieder et al., 2009b) | - Consistent changes in liver weights in rats of both sexes across four studies. Although the pattern (e.g., by sex and dose) and magnitude of changes varied across studies, weights were consistently increased. | - Other than liver-weight changes, there were notable unexplained inconsistencies in the findings across studies.; - One high-confidence study was entirely inconsistent.^a^ | Absolute or relative liver weights (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-liver-weights/) were increased in all studies except the 90-d exposure component of the study by Lieder et al. (2009a), which tested doses up to 600 mg/kg-d. Note: 70 d of exposure in this study did elicit effects.; Effects generally occurred at ≥300 mg/kg-d, although one study reported effects at lower doses (NTP, 2019; 3M, 2001), and two others (3M, 2001, 2000d) observed changes at ≥900 mg/kg-d.; Serum markers of liver injury (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-liver-effects/) were unchanged in three studies (Lieder et al., 2009a; 3M, 2001, 2000d) and increased in one short-term study at ≥250 mg/kg-d (NTP, 2019).; Liver histopathology (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-liver-effects/), specifically hepatocellular hypertrophy and cytoplasmic alterations in males and females (NTP, 2019) or hypertrophy in females only (Lieder et al., 2009a), were noted in two studies, but not in the others. | Equivocal (equivocal human and animal evidence).
Lipid or lipoprotein homeostasis
Human studies (https://hawcprd.epa.gov/rob/study/100001071/) | | | | Equivocal (equivocal human and animal evidence).
- Low-confidence cross-sectional study (Zeng et al., 2015); - Medium-confidence study (Chen et al., 2019) | - Statistically significant association in medium-confidence study of adiposity.; - Exposure response gradient observed across tertiles for adiposity. | - Single study per outcome.; - Potential for residual confounding. | Increase in total cholesterol (statistically significant, β: 19.3 mg/dL increase per unit increase in PFBS) (Zeng et al., 2015). Higher adiposity in 5-year-old children associated with higher levels of PFBS in cord blood (Chen et al., 2019). | Equivocal (equivocal human and animal evidence).
Animal studies (https://hawcprd.epa.gov/summary/visual/100000053/) | | | | Equivocal (equivocal human and animal evidence).
[underlined: Mouse Studies (diet):]; - Medium-confidence short-term (4–6 wk) study (Bijland et al., 2011); transgenic mice (human-like lipid metabolism) were fed a high-fat diet; [underlined: Rat Studies (all gavage):]; - One high-confidence subchronic study (Lieder et al., 2009a); - One high-confidence study (3M, 2001) and one medium-confidence (3M, 2000d) short-term (10–28 d) study | - Decreases in serum cholesterol and triglycerides were observed in male rats and mice. | - Inconsistent evidence in other rat studies and across sexes.; - Small effect magnitudes and unclear direction (decreases) of changes are of questionable biological relevance and could not be informed by evaluating dose-dependency (i.e., only single-dose or high-dose effects were observed). | Serum lipids (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-lipid-effects/), specifically cholesterol and triglyceride levels, were slightly decreased (~20%) at 900 mg/kg-d in males, but not females, in one rat study (3M, 2001), but not in two other rat studies at up to 1,000 mg/kg-d. Serum and hepatic lipids and lipoproteins were also decreased in male mice exposed to ~30 mg/kg-d in diet. | Equivocal (equivocal human and animal evidence).
Immune effects
Human studies (https://hawcprd.epa.gov/summary/visual/100000052/) | | | | Equivocal (equivocal human and animal evidence).
Asthma | | | | Equivocal (equivocal human and animal evidence).
- Medium-confidence case-control study (Zhou et al., 2016; Zhu et al., 2016; Dong et al., 2013b) | - Statistically significant association in a medium-confidence study.; Note: Increases in eosinophil markers were not interpreted to increase support for hazard, because they were not statistically significant and other markers important to asthma etiology (e.g., IgE) were unchanged. | - Association was observed in a single study with concern regarding the potential for residual confounding (e.g., with other PFAS chemicals). | Statistically significant increase in odds of asthma diagnosis in the previous year (OR: 1.2–1.9) with increased PFBS exposure. Eosinophil markers (i.e., AEC and ECP) were increased with increased PFBS exposure in asthmatics and nonasthmatics; however, these increases did not reach statistical significance. IgE and T-helper cell-specific cytokines were unchanged (Zhu et al., 2016). | Equivocal (equivocal human and animal evidence).
Atopic dermatitis | | | | Equivocal (equivocal human and animal evidence).
- Medium-confidence cohort study (Chen et al., 2018) | - No factors noted. | - Slight associations were not statistically significant in a single study with concern regarding the potential for residual confounding (e.g., with other PFAS chemicals). | Statistically nonsignificant increase in odds of atopic dermatitis (OR: 1.2) with increased PFBS exposure. | Equivocal (equivocal human and animal evidence).
Animal studies | | | | Equivocal (equivocal human and animal evidence).
No studies available to evaluate. | – | – | – | Equivocal (equivocal human and animal evidence).
Cardiovascular effects
Human studies | | | | Equivocal (equivocal human and animal evidence).
- Medium-confidence cross-section study (Huang et al., 2018); - Medium-confidence cross-sectional study (Huang et al., 2019b) | - Statistically significant associations in medium-confidence studies. | - Single study per outcome. | Higher odds of cardiovascular disease (total and individual types of disease) with PFBS exposure (Huang et al., 2018). Higher odds of hypertensive disorders in pregnancy with higher PFBS exposure (Huang et al., 2019b). There is potential for residual confounding that decreases confidence in the evidence. | Equivocal (equivocal human and animal evidence).
Animal studies | | | | Equivocal (equivocal human and animal evidence).
No studies available to evaluate. | – | – | – | Equivocal (equivocal human and animal evidence).

a The lack of liver effects in the subchronic study was not interpreted to significantly reduce support for hazard because the maximum tolerated dose was 600 mg/kg-d, and other studies reported only liver effects at ≥900 mg/kg-d.

AEC = absolute eosinophil count; BUN = blood urea nitrogen; BW = body weight; CPN = chronic progressive nephropathy; ECP = eosinophilic cationic protein; GD = gestation day; IgE = immunoglobulin E; NTP = National Toxicology Program; OR = odds ratio; PFAS = per- and polyfluoroalkyl substances; PFBS = perfluorobutane sulfonic acid; PND = postnatal day; T_3_ = triiodothyronine; T_4_ = thyroxine; TSH = thyroid stimulating hormone.