# 4.0 EVIDENCE SYNTHESIS: OVERVIEW OF INCLUDED STUDIES

The database of all repeated-dose oral toxicity studies for PFBS and the related compound K^+^PFBS that are potentially relevant for deriving RfD values includes a short-term range-finding study in rats (3M, 2000d), two 28-day studies in rats (NTP, 2019; 3M, 2001), one subchronic study in rats (Lieder et al., 2009a; York, 2003b), one subchronic-duration lipoprotein metabolism study in mice (Bijland et al., 2011; 3M, 2010), three gestational exposure studies in mice and rats (Feng et al., 2017; York, 2003a, 2002), and a two-generation reproductive toxicity study in rats (Lieder et al., 2009b; York, 2003c, d, e). In addition, 19 epidemiological studies (described in 22 publications) were identified that report on the association between PFBS and human health effects. Specific study limitations identified during evaluation (see HAWC) are discussed only for studies interpreted as low confidence or if a limitation affected a specific inference for drawing conclusions.

Human and animal studies have evaluated potential effects on the thyroid, reproductive systems, development, kidneys, liver, and lipid and lipoprotein homeostasis following exposure to PFBS. The evidence base for these outcomes is presented in this section. For each potential health effect, the synthesis describes the database of human and animal studies, as well as an array of the animal results across studies. NOAELs and LOAELs presented in the figures and text are based on statistical significance and/or biological significance (e.g., directionality of effect [statistically significantly decreased cholesterol/triglycerides is of unclear toxicological relevance], abnormal or irregular dose-response relationship [nonmonotonicity], tissue-specific considerations for magnitude of effect [statistically nonsignificant increase of ≥10% in liver weight interpreted as biologically significant]). A summary of the available database is presented in Table 6 of Section 5. For information in this section, evidence to inform organ/system-specific effects of PFBS in animals following developmental exposure is discussed in the individual organ/system-specific sections (e.g., reproductive cycling endpoints after developmental exposure are discussed in the “Reproductive Effects” section). Other effects informing potential developmental effects (e.g., pup BW) are discussed in the “Offspring Growth and Early Development” section.

Evidence integration analyses and overall judgments on the hazard support for each outcome domain provided by the available human and animal studies are discussed in the “Evidence Integration and Hazard Characterization” section. Notably, in that section, the evidence informing organ/system-specific endpoints after developmental exposure was considered potentially informative to both the developmental effects outcome domain and the organ/system-specific outcome domain.

## 4.1 THYROID EFFECTS

### 4.1.1 Human Studies

One low-confidence (https://hawcprd.epa.gov/rob/study/100515513/) study examined cross-sectional associations between PFBS exposure and thyroid hormones in women with premature ovarian insufficiency (Zhang et al., 2018) and reported no association with free T_3_, free T_4_, or thyroid-stimulating hormone. However, this study had poor sensitivity and methodological limitations that make interpreting these null results difficult; further, the results in this highly selected population may not be generalizable.

### 4.1.2 Animal Studies

Two high-confidence studies evaluated the effects of PFBS exposure on the thyroid, specifically thyroid hormone levels, thyroid histopathology, and thyroid weight (NTP, 2019; Feng et al., 2017) (see Figure 7). Dams exposed to K^+^PFBS through gestation (GDs 1–20) exhibited a statistically significant decrease in total triiodothyronine (T_3_) (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/), total thyroxine (T_4_) (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/), and free T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/) (reduced 17, 21, and 12%, respectively, relative to control at 200 mg/kg-day and reduced 16, 20, and 11%, respectively, relative to control at 500 mg/kg-day) on GD 20 at doses of 200 and 500 mg/kg-day, but not at 50 mg/kg-day (Feng et al., 2017). Decreased total T_3_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/) and total T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/) were also reported at PNDs 1, 30, and 60 in offspring gestationally exposed to K^+^PFBS at the same doses (up to 37% reduction in T_3_ and 52% reduction in T_4_). Increased thyroid-stimulating hormone (TSH (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-tsh-effect-size-animal/)) was reported in dams and pubertal (PND 30) offspring (21 and 14% relative to control at 200 mg/kg-day, respectively) exposed gestationally to K^+^PFBS. Statistically significant dose-dependent decreases in total T_3_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/), total T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/), and free T_4_ (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/) were also reported after exposure in male and female rats to K^+^PFBS for 28 days at all doses tested (≥62.6 mg/kg-day) (NTP, 2019). The reported reductions in rat total T_3_ were up to −57% (male) and −43% (female), in free T_4_ up to −86% (male) and −77% (female), and in total T_4_ up to −97% (male) and −71% (female). Dose-response graphics for T_4_, T_3_, and TSH, including effect size and variability, are included in Appendix E, Figures Figure E-1, Figure E-2, and Figure E-3, respectively. Thyroid gland weight, thyroid histopathology, and TSH levels (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-tsh-effect-size-animal/) were not changed after 28 days of PFBS exposure in male or female rats at doses up to 1,000 mg/kg-day (NTP, 2019).

Figure 7 Thyroid Effects from K^+^PFBS Exposure

(Click to see interactive data graphic and rationale for study evaluations for effects on the thyroid (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-thyroid-effects/) in HAWC)

Figure 7 presents a dose-response array for studies that evaluated the effects of oral PFBS exposure on the thyroid. The array is a static representation of information presented in the Health Assessment Workspace Collaborative (HAWC) web platform. The figure shows doses ranging from 0 up to 1,000 mg/kg-day across thyroid hormone measures such as total or free thyroxine (T4), triiodothyronine (T3), and thyroid stimulating hormone (TSH), as well as thyroid tissue weight or histopathology. Where PFBS induced an effect, a red triangle indicates a decrease in an endpoint and a green triangle indicates an increase. In general, the array shows that oral PFBS decreases total and free T4 and T3 in a dose-dependent manner in neonatal, juvenile, and adult mice, or adult rats after exposure for up to 28 days. The figure also shows that thyroid tissue weight and histopathology were not observed in rats following 11 or 28 days of repeated PFBS exposure via the oral route.

## 4.2 REPRODUCTIVE EFFECTS

### 4.2.1 Human Studies

Five studies of populations in China and Taiwan examined different reproductive outcomes in women and men (Yao et al., 2019; Song et al., 2018; Zhang et al., 2018; Zhou et al., 2017a; Zhou et al., 2016).

Three low-confidence (https://hawcprd.epa.gov/rob/study/100000898/) studies examined reproductive hormones in newborn boys and girls in China (Yao et al., 2019), adolescent boys and girls in Taiwan (Zhou et al., 2016), and adult women in China (Zhang et al., 2018). The study in newborns reported lower testosterone (β: −0.23; 95% CI: −0.46−0.01) and estradiol (β: −0.09; 95% CI: −0.2−0.01) in cord blood in male babies, but these differences were not statistically significant (Yao et al., 2019). The other two studies reported no clear associations between PFBS levels and reproductive hormones in women with premature ovarian insufficiency (Zhang et al., 2018) or in adolescents, either among the entire study population or stratified by sex (Zhou et al., 2016).

One low-confidence (https://hawcprd.epa.gov/rob/study/100001467/) cross-sectional study (Song et al., 2018) examined the association between PFBS exposure and semen parameters. There was no indication of decreased semen quality in this study (correlation coefficients of −0.022 for semen concentration and 0.195 [p < 0.05] for progressive motility), although issues were noted regarding the ability of this study to detect an effect and important methodological details were missing.

Two studies examined other female reproductive effects: a cross-sectional study of menstrual cycle characteristics in a general population sample of women planning to become pregnant who were enrolled at preconception care clinics in China (Zhou et al., 2017a) and a case-control study in China of premature ovarian insufficiency (Zhang et al., 2018), defined by FSH level and oligo/amenorrhea. For any outcome related to menstruation, there is significant potential for reverse causation because menstruation is a potential mechanism by which PFAS are removed from the body (Wong et al., 2014; Zhang et al., 2013); therefore, both of these studies are considered low confidence. Zhou et al. (2017a) reported adjusted odds ratios (OR) of 1.30 (95% CI: 0.54–3.12) for menorrhagia and 1.48 (95% CI: 0.54–4.03) for hypomenorrhea in preconception women in China for each one unit increase in PFBS, but these results were not statistically significant. The study authors also reported inverse statistically nonsignificant associations for these two outcomes based on exposure quartiles (OR range: 0.61–0.84 for the highest quartiles relative to the referent) with no evidence of an exposure-response relationship, indicating that the associations are not robust. All of the analyses in this study examined continuous outcome measures. Zhang et al. (2018) reported no increase in odds of premature ovarian insufficiency with higher PFBS exposure (OR for tertile 2 vs. tertile 1: 0.84, 95% CI: 0.44–1.60; OR for tertile 3: 0.92, 95% CI: 0.48–1.76).

### 4.2.2 Animal Studies

Reproductive outcomes were evaluated in a high-confidence study of prenatal exposure to PFBS in mice (Feng et al., 2017), in two high-confidence gestational exposure studies in rats (York, 2003c, 2002), in high-confidence short-term and subchronic studies in rats [NTP (2019) and Lieder et al. (2009a), respectively], and in a high-confidence two-generation reproductive study in rats (Lieder et al., 2009b). Endpoints evaluated in these studies include fertility and pregnancy outcomes, hormone levels, markers of reproductive development, and reproductive organ weights.

#### 4.2.2.1 Female Fertility and Pregnancy Outcomes

Female fertility parameters were evaluated by both Feng et al. (2017) and Lieder et al. (2009b), who reported generally no effects in exposed parents, but some effects after gestational exposure in the F_1_ offspring (click to see interactive graphic for female fertility effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-female-fertility-effects/) in HAWC). Female fertility (e.g., fertility index and days in cohabitation) and delivery parameters (e.g., length of gestation, % deliveries, stillborn pups, and implantation sites) evaluated in Lieder et al. (2009b) were generally unaffected by K^+^PFBS treatment for P_0_- and F_1_-generation dams at doses up to 1,000 mg/kg-day. The mean number of live born F_1_ pups was statistically significantly decreased in the 30-mg/kg-day group, but this change was not dose dependent. The viability index in F_1_ pups and the lactation index in F_1_ and F_2_ pups showed statistically significant changes at various doses but were not dose dependent (Lieder et al., 2009b). Similarly, no effects were observed in delivery and litter parameters (e.g., implantations, litter sizes, live fetuses, corpora lutea, and early resorptions) following prenatal exposure from GDs 6 to 20 (York, 2003c, 2002). Adult (PND 60) F_1_ females gestationally exposed to PFBS at doses ≥200 mg/kg-day, however, exhibited fewer primordial, primary, secondary, early antral, antral, and preovulatory follicles, as well as fewer corpora lutea than control animals (Feng et al., 2017). Importantly, no effects on the health (e.g., weight gain) of the exposed dams were observed at any dose (Feng et al., 2017). Lieder et al. (2009b) evaluated ovarian follicles in F_1_ females after they were mated and their pups had been weaned (i.e., Lactation Day [LD] 22) and observed no effects compared with controls at 1,000 mg/kg-day; however, no quantitative data were reported. Ovarian parameters were not evaluated in the study by York (2002).

#### 4.2.2.2 Male Fertility

Two studies using S-D rats evaluated several potential responses in the male reproductive system (NTP, 2019; Lieder et al., 2009b). Male fertility parameters and reproductive effects (e.g., sperm parameters) were generally unaffected by K^+^PFBS treatment in P_0_- and F_1_-generation males observed by Lieder et al. (2009b). At the highest dose, there were statistically significant increases in the percentage of abnormal sperm in F_1_ animals and decreases in testicular sperm count in P_0_-generation males. In addition, the study authors reported that the number of spermatids per gram testis was within the historical control of the testing facility. These effects were not statistically changed at lower doses. Alterations in parameters such as sperm count/number and morphology are considered indicative of adverse responses in the male reproductive system (Foster and Gray, 2013; Mangelsdorf et al., 2003; U.S. EPA, 1996a). A 28-day exposure study reported a decreased trend in testicular spermatid count per mg testis evaluated at the time of necropsy; however, no significant effects on other sperm measures were reported, including caudal epididymal sperm count and sperm motility (NTP, 2019). Note that a complete spermatogenesis cycle in male rats is typically 7 weeks in length, thus study designs of shorter duration could potentially miss effects of chemical exposure on some sperm parameters. Accordingly, the differences in responses observed in the two available studies might have been due to experimental design differences, because Lieder et al. (2009b) exposed P_0_ animals for 70 days and F_1_ animals during the entire period of gestation plus lactation, whereas NTP (2019) exposed animals for 28 days. Future studies should be conducted to determine whether long-term and/or gestational exposure to PFBS significantly affects sperm measures in sexually mature and developing animals.

#### 4.2.2.3 Reproductive Hormones (Female and Male)

Reproductive hormones were evaluated in mice (Feng et al., 2017) and, to a limited extent, in rats (NTP, 2019) (see Figure 8). Exposure to K^+^PFBS for 28 days resulted in a significant trend for increased testosterone levels in females, but not in males (NTP, 2019). The increase in testosterone was not statistically significant when compared to control at any dose by pairwise analysis. Prenatal exposure to PFBS at and above 200 mg/kg-day resulted in statistically significant reduced serum estradiol levels and increased serum luteinizing hormone levels in pubertal offspring (i.e., PND 30) (Feng et al., 2017). The change in serum estradiol levels, but not luteinizing hormone, continued into adulthood in the K^+^PFBS-exposed offspring (i.e., PND 60). Adult PFBS-exposed offspring also exhibited decreased serum progesterone levels at doses of 200 mg/kg-day and greater. PFBS exposure did not alter maternal estradiol-, progesterone-, or gonadotropin-releasing hormone. Reproductive hormone levels in males and females were not evaluated by Lieder et al. (2009b). The changes in follicle and corpora lutea development reported in the same study, however, may be associated with alterations in hormone production/levels because ovarian follicles and corpora lutea produce estrogen and progesterone, respectively (Foster and Gray, 2013; U.S. EPA, 1996a).

The hormonal effects observed in the NTP (2019) and Feng et al. (2017) studies might be associated with adverse reproductive effects reported in these studies. Androgens, luteinizing hormone, estradiol, and progesterone play an important role in normal development and in the functioning of the female reproductive system (Woldemeskel, 2017; Foster and Gray, 2013). Alterations in the levels and production of these reproductive hormones can disrupt endocrine signals at the hypothalamic-pituitary level and lead to delayed reproductive development and changes in functions (Rudmann and Foley, 2018; Woldemeskel, 2017; Foster and Gray, 2013).

Figure 8 Reproductive Hormone Response to K^+^PFBS Exposure

(Click to see interactive data graphic and rationale for study evaluations for reproductive hormone levels (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-hormone-effects2/) in HAWC)

Plot of data evaluating reproductive hormone responses to K+PFBS in animals. The figure shows doses ranging from 0 up to 1,100 mg/kg-day. Hormones listed are Testosterone, Estrogen, Progesterone, Luteinizing Hormone, and Gonadotropin Releasing Hormone. Significant decreases in estrogen were observed at all doses in PND30 and PND60 mice. Significant decreases in progesterone were observed at all doses in PND60 mice. Significant increases in luteinizing hormone were observed at all doses in PND30 mice. There were no changes in all other hormones across studies.

#### 4.2.2.4 Reproductive System Development, Including Markers of Sexual Differentiation and Maturation (Female and Male)

Several measures of female reproductive development were affected by gestational K^+^PFBS exposure in mice (see Figure 9, Figure E-5, and Figure E-6). Feng et al. (2017) reported a delayed first estrous in female PFBS-exposed offspring (≥200 mg/kg-day) compared with control (see Figure E-5). Estrous cyclicity was also affected in K^+^PFBS-exposed PNDs 40–60 offspring as exhibited by a prolongation of the diestrus stage compared with control. Estrous cycling was generally not statistically significantly altered in P_0_- or F_1_-generation females treated with K^+^PFBS in the two-generation study by Lieder et al. (2009b). An increase in the number of rats with ≥6 consecutive days of diestrus was observed in the F_1_ females exposed to 100 mg/kg-day; however, the increase was not present at higher doses (Lieder et al., 2009b). Estrous cyclicity was affected after adult exposure to K^+^PFBS for 28 days as shown by a dose-dependent prolongation of diestrus at doses of 250 mg/kg-day and greater with marginal significance at the lowest dose tested (125 mg/kg-day) (p = 0.063) (NTP, 2019). Lieder et al. (2009b) reported a delay in the days to preputial separation in F_1_ males of the 30- and 1,000-mg/kg-day groups;^10^ however, the measure was no longer statistically significant when adjusted for BW. There was similarly no change in the days to vaginal patency in F_1_ female rats (Lieder et al., 2009b). Unlike Lieder et al. (2009b), Feng et al. (2017) reported a delay in vaginal patency in F_1_ females after gestational exposure of 200 mg/kg-day and greater (see Figure E-6).

Figure 9 Effects on Reproductive Development and Estrous Cycling Following PFBS Exposure

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-development/))

Figure 9 presents a dose-response array for studies that evaluated the effects of oral PFBS exposure on reproductive development and estrous cycling. The array is a static representation of information presented in the Health Assessment Workspace Collaborative (HAWC) web platform. The figure shows doses ranging from 0 up to 1,000 mg/kg-day across single-generation, two-generation, and 28-day studies in rats or mice. The effects captured in this array include estrus, diestrus, metestrus, proestrus, vaginal opening, and vaginal patency in adult parental female rodents or in female offspring at birth or up to postnatal day 60. Preputial separation in developing male rats is also presented. The results demonstrate that oral PFBS induced prolongation of diestrus in adult rats and rats and mice during postnatal development at doses greater than or equal to 100 mg/kg-day. At postnatal day 60, mice exposed in utero to PFBS at doses greater than or equal to 200 mg/kg-day experienced delayed vaginal opening.

#### 4.2.2.5 Reproductive Organ Weights and Histopathology (Female and Male)

Studies have not consistently reported changes in reproductive organ weights (click to see interactive graphic for reproductive organ effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-reproductive-organ-effects/) in HAWC). Reproductive organ weights, including testes, ovaries, and uterus, were unchanged in the two-generation reproductive study in P_0_ and F_1_ males and females (Lieder et al., 2009b) and following short-term and subchronic exposure to K^+^PFBS (NTP, 2019; Lieder et al., 2009a; 3M, 2001, 2000d). F_1_ females gestationally exposed to PFBS, however, exhibited decreased size and weight of the ovaries and uterus (Feng et al., 2017). In addition, the total uterine section diameter and endometrial and myometrial thickness were significantly reduced. There were no significant histopathological alterations in the male or female reproductive organs evaluated following exposure to K^+^PFBS for 28 days (NTP, 2019) or in parental or offspring from the two-generation reproductive study (Lieder et al., 2009b).

## 4.3 OFFSPRING GROWTH AND EARLY DEVELOPMENT

### 4.3.1 Human Studies

No human studies were available to inform the potential for PFBS exposure to cause effects on the growth or early development of children.

### 4.3.2 Animal Studies

Evidence to inform organ/system-specific effects of PFBS in animals following developmental exposure are discussed in the individual hazard sections (e.g., reproductive cycling after developmental exposure is discussed in the “Reproductive Effects” section). This section is limited to discussion of other, specific developmental effects commonly evaluated in guideline developmental toxicity studies, including pup BW, developmental markers, and bone measures. Four high- or medium-confidence studies examined potential alterations in offspring growth and early development following PFBS exposure, including two gestational exposure studies in rats (York, 2003a, 2002) and one gestational exposure study in mice (Feng et al., 2017), as well as a two-generation study in rats (Lieder et al., 2009b; York, 2003c). (Click to see interactive graphic for developmental effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-developmental-effects/) in HAWC.)

None of the studies identified significant effects in either rats or mice on measures of fetal morphology (i.e., malformations and variations). BW of female offspring of PFBS-exposed mice at doses greater than 200 mg/kg-day was statistically significantly lower than control at PND 1, and the pups remained underweight through weaning, pubertal, and adult periods, with decreases of approximately 25% observable in pups nearing weaning (Feng et al., 2017). At around PND 16, Feng et al. (2017) also reported an ~1.5-day developmental delay in eye opening in pups gestationally exposed to 200 mg/kg-day PFBS and greater. Importantly, no effects on the health of the exposed dams (e.g., weight gain) were observed at any dose (Feng et al., 2017). Dose-response graphics (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-eye-opening-effect-size-animal/) for eye opening, including effect size and variability, are included in Appendix E, Figure E-4. Fetal BWs (male and female) were also reduced (approximately 10%) compared with controls following gestational exposure from GDs 6 to 20 at the highest tested dose (1,000 mg/kg-day in York (2002) and 2,000 mg/kg-day in York (2003a)]). Parental BWs and organ weights, however, were also affected to a similar degree at those doses (Lieder et al., 2009b; York, 2003c, 2002), limiting the interpretation of the results. No statistically significant changes in F_1_- and F_2_-generation pup mean pup weight at birth and mean pup weight at weaning were reported by Lieder et al. (2009b) or York (2003c).

Several measures of thyroid hormone development and female reproductive development were affected by gestational PFBS exposure in mice and are described in more detail in the “Thyroid Effects” and “Reproductive Effects” sections, respectively.

## 4.4 RENAL EFFECTS

### 4.4.1 Human Studies

One low-confidence (https://hawcprd.epa.gov/rob/study/100001468/) study (Qin et al. (2016), with additional details in Bao et al. (2014), selected 225 subjects ages 12–15 years old from a prior cohort study population in seven public schools in northern Taiwan (Tsai et al., 2010) and examined the association between PFBS exposure and uric acid concentrations. There was no association between ln(PFBS) concentration and uric acid concentrations in the total population (β: 0.0064 mg/dL increase in uric acid per 1 ln-μg/L increase in PFBS; 95% CI: −0.22−0.23). U.S. EPA identified that a nonsignificant positive association in boys was offset by a nonsignificant negative association in girls, and there is not enough information to determine whether there is a sex dependence. When PFBS exposure was analyzed for high uric acid (>6 mg/dL), the risk was somewhat elevated in boys (OR: 1.53; 95% CI: 0.92–2.54), but not in girls (OR: 0.99; 95% CI: 0.58–1.73). The potential for reverse causation (i.e., that renal function could influence the levels of PFBS in the blood) tempers any conclusions that might be drawn.

### 4.4.2 Animal Studies

Renal effects were evaluated in high-confidence short-term and subchronic-duration exposure studies in rats (NTP, 2019; Lieder et al., 2009a; 3M, 2001, 2000d) and in a high-confidence two-generation reproductive study in rats (Lieder et al., 2009b). Endpoints evaluated in these studies include kidney weights, histopathological changes, and serum biomarkers of effect (see Figure E-8 and Figure E-9). Dose-response graphics for histopathological effects, including effect size and variability, are included in Appendix E, Figure E-7.

Absolute and relative kidney weights of males and females were unchanged in S-D rats exposed daily for 90 days to K^+^PFBS at doses up to 600 mg/kg-day compared with control rats (Lieder et al., 2009a). This lack of effect on kidney weight was also observed in parental and F_1_ male and female rats of the same strain exposed to K^+^PFBS at doses up to 1,000 mg/kg-day during a two-generation reproductive study (Lieder et al., 2009b). Although none of the findings reached statistical significance, an approximate 9% increase in absolute kidney weight was observed in female S-D rats exposed to 1,000 mg/kg-day K^+^PFBS for 10 days (3M, 2000d); relative-to-body kidney weights were also increased approximately 6–9%. This organ-weight effect was not observed in corresponding males of the study. In a follow-up 28-day study by the same lab, a 9–11% increase in absolute and relative-to-body kidney weight was observed in female S-D rats exposed to 900 mg/kg-day K^+^PFBS (3M, 2001), although these changes were not statistically significant. In this study, U.S. EPA also observed that smaller nonsignificant increases in kidney weight occurred in male rats. In another 28-day study, K^+^PFBS exposure significantly increased absolute and relative right kidney weights in high-dose (500 mg/kg-day) male S-D rats (NTP, 2019). Only relative kidney weights were altered in female rats, but this effect was significant at all tested K^+^PFBS doses (≥62.6 mg/kg-day). Click to see interactive graphic for kidney-weight effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-renal-effects-2/) in HAWC.

After 90 days of exposure, Lieder et al. (2009a) observed increased incidences of histopathological alterations of the kidneys of male and female rats of the high-dose group (600 mg/kg-day). Increased incidence of hyperplasia (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-histopathology-effect-size-animal/) of the epithelium of renal papillary tubules and ducts was observed in rats of both sexes (see Figure E-7 Figure E-8). A single incidence of papillary necrosis in both kidneys was observed in one male in the high-dose group. Further, focal papillary edema was observed in 3/10 rats of both sexes of the high-dose groups compared with no evidence of this effect in control rats. Similar histopathological alterations were observed in parental and F_1_ male and female rats in the two-generation reproduction study (Lieder et al., 2009b). Compared with control rats, increased incidences of hyperplasia (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-histopathology-effect-size-animal/) of the renal tubular and ductal papillary epithelium, and focal papillary edema were observed in parental male and female rats at PFBS doses ≥300 mg/kg-day. Hyperplastic foci in the same locations of the kidney were also observed in male and female F_1_ rats exposed to ≥300 mg/kg-day PFBS across life stages from gestation to adulthood (Lieder et al., 2009b). Focal papillary edema was observed in male (≥1,000 mg/kg-day) and female (≥300 mg/kg-day) F_1_ rats, although this specific alteration did not appear to be dose-dependent in females. Although kidney alterations such as hydronephrosis, mineralization, and tubular degeneration were observed in male or female S-D rats after just 10 days of oral K^+^PFBS exposure, these effects were not significant compared to control and/or did not appear to be dose-dependent (3M, 2000d). The same histopathological lesions were noted in the 28-day rat study albeit with lack of statistical significance compared to control (3M, 2001). In another 28-day gavage study in S-D rats, chronic progressive nephropathy (CPN) was observed in all male and female PFBS treatment groups and control rats, with no evidence of dose dependence for this effect (NTP, 2019). Renal papillary necrosis was also observed in these rats but only at the highest exposure dose (1,000 mg/kg-day).

Serum levels of biomarkers indicative of kidney injury and/or function, including blood urea nitrogen (BUN) and creatinine, have been examined across multiple studies of varying exposure durations, and were found to be unchanged in male and female rats treated with K^+^PFBS at doses up to 1,000 mg/kg-day (Lieder et al., 2009a; 3M, 2001, 2000d). After 28 days of gavage exposure in S-D rats, however, NTP (2019) observed significantly increased levels of BUN in males (≥250 mg/kg-day). This increased circulating BUN was not observed in female rats at doses up to 1,000 mg/kg-day. Click to see interactive graphic for other kidney effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-effects-kris-v3/) in HAWC.

## 4.5 HEPATIC EFFECTS

### 4.5.1 Human Studies

No human studies were available to inform the potential for PFBS exposure to cause hepatic effects.

### 4.5.2 Animal Studies

Hepatic effects were evaluated in high-confidence short-term and subchronic studies in rats (NTP, 2019; Lieder et al., 2009a; 3M, 2001, 2000d) and in a high-confidence two-generation reproductive study in rats (Lieder et al., 2009b). Endpoints evaluated in these studies include liver weights, histopathological changes, and serum biomarkers of effect (see Figure E-10).

Ten days of daily gavage exposure to K^+^PFBS significantly increased absolute, relative-to-body, and relative-to-brain weights of liver in adult male and female S-D rats exposed to 1,000 mg/kg-day (3M, 2000d). The absolute liver mass of male rats was increased by 36% compared with females (22%). A similar profile of liver-weight alteration in S-D rats was observed following 28 days of exposure wherein absolute and relative liver weights of high-dose (900 mg/kg-day) male rats had increased 25%–30% (3M, 2001). Female rats at the same treatment dose did not experience a similar magnitude increase in absolute or relative liver weights (4–6%). In another 28-day study in S-D rats, K^+^PFBS exposure significantly increased absolute and relative liver weights in males (≥125 and ≥62.6 mg/kg-day, respectively) and females (≥250 and ≥125 mg/kg-day, respectively) (NTP, 2019). In contrast, the livers of male and female S-D rats exposed to K^+^PFBS at doses up to 600 mg/kg-day for 90 days were not significantly changed compared with respective controls (Lieder et al., 2009a). In a two-generation reproduction study using the same strain of rat, however, increased absolute and relative liver weights were observed in male parental rats exposed to doses of K^+^PFBS ≥300 mg/kg-day for approximately 70 days (Lieder et al., 2009b). In the F_1_ adult males, only relative liver weight was significantly increased at the high dose (1,000 mg/kg-day), although terminal BW was significantly decreased in this group compared with control.

Histopathological examination of the livers of S-D rats across three separate gavage studies of increasing K^+^PFBS exposure duration [10-day, 3M (2000d); 28-day, 3M (2001); 90-day, Lieder et al. (2009a)] did not reveal any significant dose-dependent alterations or lesions. For example, focal/multifocal hepatic inflammation was observed in 3/10 male and 4/10 female rats of the high-dose group (no incidence at the low or mid dose) compared to 6/10 male and female rats in the control groups (Lieder et al., 2009a). The Lieder et al. (2009b) two-generation reproduction gavage study did identify increased incidences of hepatocellular hypertrophy in parental and F_1_ adult male rats at ≥300 mg/kg-day; however, this effect was absent in female rats at doses of K^+^PFBS up to 1,000 mg/kg-day. NTP (2019) identified a significantly increased incidence of hepatocellular hypertrophy in male (≥125 mg/kg-day) and female (≥500 mg/kg-day) S-D rats after 28 days of K^+^PFBS exposure. Further, significantly increased cytoplasmic alteration of hepatocytes was observed in these rats (male and female at ≥500 mg/kg-day). Hepatic necrosis was also observed but was not significant compared with control and only occurred at the high dose (1,000 mg/kg-day) in both sexes (NTP, 2019).

In general, serum biomarkers associated with altered liver function or injury, including alanine aminotransferase (ALT) and aspartate aminotransferase (AST), were not significantly changed in male and female S-D rats across multiple gavage studies of varying exposure durations up to 90 days and at K^+^PFBS doses up to 1,000 mg/kg-day (Lieder et al., 2009a; 3M, 2001, 2000d). NTP (2019), however, reported increased serum ALT and AST in male (500 mg/kg-day only) and female (≥250 mg/kg-day for ALT; ≥500 mg/kg-day for AST) rats exposed to K^+^PFBS for 28 days. Click to see interactive graphic for liver effects (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-liver-effects/) in HAWC.

## 4.6 EFFECTS ON LIPIDS OR LIPOPROTEINS

### 4.6.1 Human Studies

One low-confidence study (Zeng et al., 2015) used the controls from the case-control study of asthma described below (Dong et al., 2013a) and examined the association between PFBS exposure and serum lipids. There was a statistically significant increase in total cholesterol (β: 19.3 mg/dL increase per 1 μg/L increase in PFBS; 95% CI: 0.6–38.0) but when PFBS exposure was analyzed in quartiles, no exposure-response gradient was observed.

In addition, a medium-confidence (https://hawcprd.epa.gov/rob/study/100515514/) birth cohort study in China examined associations with childhood adiposity (Chen et al., 2019). PFBS was measured in cord blood samples at birth and several measures of adiposity were collected at age 5 years. There was higher adiposity with higher exposure in girls, with significant exposure-response relationships across tertiles with waist circumference, fat mass, body fat percentage, and waist-to-height ratio. No association with adiposity was observed in boys. It is unlikely that the association in girls can be explained by confounding across the other PFAS measured in this study as the associations were strongest for PFBS, but it is possible that there is other unmeasured confounding.

### 4.6.2 Animal Studies

Beyond a single medium-confidence mouse study [Bijland et al. (2011); 3M (2010); summarized below], PFBS studies have not particularly focused on perturbations in lipids or lipoproteins as a potential health outcome, because studies have typically focused only on measures of serum cholesterol and triglyceride as part of a broader panel of clinical chemistry measures in high- or medium-confidence rat studies of 10, 28, and 90 days (see Figure E-11) [3M (2000d), 3M (2001), and Lieder et al. (2009a), respectively]. Circulating levels of cholesterol and triglycerides were unchanged in male and female S-D rats following daily gavage exposure to K^+^PFBS for 10 days at doses up to 1,000 mg/kg-day (3M, 2000d). In a similarly designed study from the same laboratory, serum cholesterol and triglyceride levels were decreased in male rats but at the high dose only, and this effect was neither statistically significant compared with control nor observed in female rats of the same dose group (3M, 2001). Following exposure for up to 90 days, cholesterol and triglycerides were unchanged in male and female rats at doses up to 600 mg/kg-day (Lieder et al., 2009a). PFBS was included in a multi-PFAS study specifically designed to interrogate the mechanism of effect on lipid and lipoprotein metabolism in a transgenic mouse line (APOE*3-Leiden CETP) that is highly responsive to fat and cholesterol intake, consistent with human populations exposed to a western-type diet (containing 14% beef tallow, 1% corn oil, and 0.25% cholesterol) (Bijland et al., 2011; 3M, 2010). Adult male mice were fed a western-type, high-fat diet for 4 weeks prior to initiation of PFBS exposure and throughout the 4- to 6-week PFBS exposure period (at approximately 30 mg/kg-day). This study included several measures of lipid and lipoprotein synthesis, modification, and transport or clearance, such as circulating plasma levels, in vivo clearance of very low-density lipoprotein (VLDL)-like particles, fecal bile acid and sterol excretion, hepatic lipid levels, lipase activity, VLDL-triglyceride and VLDL-apoB production, and gene expression profiles. After 4 weeks of PFBS exposure, fasting plasma triglycerides, cholesteryl ester transfer protein, and glycerol were significantly decreased compared with mice on the control diet. Further, the half-life of VLDL-like particles and hepatic lipase activity, and hepatic cholesteryl ester and free cholesterol levels were decreased (Bijland et al., 2011; 3M, 2010). Hepatic uptake of VLDL-like particles (represents fatty acid/lipid transport into hepatic tissue) was modestly, but significantly, increased compared with control mice. This increased hepatic lipid uptake in the liver was accompanied by increased expression of genes associated with lipid binding, activation, and metabolism (e.g., β-oxidation).

## 4.7 OTHER EFFECTS

### 4.7.1 Human Studies

Two studies in China examined different immune outcomes in children (Chen et al., 2018; Dong et al., 2013a).

One medium-confidence (https://hawcprd.epa.gov/rob/study/100000894/) study reported in five publications (Qin et al., 2017; Zhou et al., 2017b; Zhou et al., 2017a; Zhu et al., 2016; Dong et al., 2013b) examined the association between PFBS exposure and asthma, asthma symptoms, pulmonary function, and related immune markers (immunoglobulin E [IgE], absolute eosinophil count [AEC], eosinophilic cationic protein [ECP], T-helper cell-specific cytokines, and 16-kDa club cell secretory protein). The primary finding was a statistically significant (in the fourth quartile) positive association between incident asthma (i.e., diagnosis in the previous year) and PFBS exposure (OR for Q2: 1.3, 95% CI: 0.7–2.3; OR for Q3: 1.2, 95% CI: 0.7–2.2; OR for Q4: 1.9, 95% CI: 1.1–3.4). There were also increases in AEC and ECP with increased exposure (not statistically significant with the exception of AEC in children with asthma). There was no clear association with IgE or T-helper cell-specific cytokines. There was also no clear association with asthma severity or control of asthma symptoms (Dong et al., 2013a), or pulmonary function measured with spirometry among children with asthma (Qin et al., 2017). While reduced pulmonary function could be considered an outcome separate from asthma, the study authors noted no associations in pulmonary function (i.e., in nonasthmatics across the PFAS they studied), so for these purposes, it was considered an indicator of asthma severity.

One medium-confidence (https://hawcprd.epa.gov/rob/study/100001480/) study (Chen et al., 2018) examined the association between PFBS exposure and atopic dermatitis and reported a statistically nonsignificant increase in atopic dermatitis with increased exposure (OR: 1.23; 95% CI: 0.74–2.04).

In addition, two studies examined cardiovascular effects (Huang et al., 2019b; Huang et al., 2018), but it is difficult to evaluate consistency across studies given the different outcomes in each.

One medium-confidence (https://hawcprd.epa.gov/rob/study/100515512/) study (Huang et al., 2018) using data from NHANES cycles for 1999–2014 reported significantly higher odds of total cardiovascular disease with higher exposure (OR for above vs. below the LOD: 1.19; 95% CI: 1.06–1.32) and elevated, though not statistically significant, odds of individual types of cardiovascular disease (congestive heart failure, coronary heart disease, angina pectoris, heart attack, and stroke). There is potential in this study for confounding across the PFAS, because PFBS was highly correlated with some other PFAS with slightly stronger associations.

A medium-confidence (https://hawcprd.epa.gov/rob/study/100515515/) cross-sectional study (Huang et al., 2019b) of hypertensive disorders of pregnancy reported higher odds for all such disorders in pregnancy (in the third tertile) (OR for Tertile 2 vs. Tertile 1: 0.89, 95% CI: 0.39–2.44; OR for Tertile 3: 2.26, 95% CI: 1.02–5.0; p-trend 0.03) and pre-eclampsia (OR for Tertile 2 vs. Tertile 1: 2.09, 95% CI: 0.51–8.53; OR for Tertile 3: 3.51, 95% CI: 0.94–13.2; p-trend 0.05), with both trends being statistically significant after mutual adjustment of PFAS.

### 4.7.2 Animal Studies

Other effects were evaluated following exposure to PFBS, including outcomes related to the spleen, hematological system, BW, neurotoxicity, and nonspecific clinical chemistry. These groups of outcomes were not synthesized because of inadequate available information, uncertain biological relevance, and/or inconsistencies across studies and sexes.

## 4.8 OTHER DATA

Other studies that used PFBS or K^+^PFBS are described in this section. These studies are not adequate for determining RfD values and were considered supportive data. These data might include acute-duration exposures, genotoxicity, mechanistic, and other studies (see Table 5).

Table 5 Other Studies

Test | Materials and Methods | Results | Conclusions | References
Genotoxicity
Mutagenicity test | Salmonella typhimurium (strains TA98 and TA100) and Escherichia coli (strain pKM101) in the presence or absence of S9. Concentrations of PFBS were between 0–5,000 μg/plate. | Test was negative for TA100 and pKM101 strains and equivocal for TA98 strain. | There is no in vitro evidence of PFBS mutagenicity. | NTP (2005)
Ames | S. typhimurium (strains TA98, TA100, TA1535, and TA1537) and E. coli (strain WP2uvrA) were tested in the presence or absence of S9 and with or without a preincubation treatment. Concentrations of K^+^PFBS were between 0–5,000 μg/plate. | The results of both mutation assays indicate that PFBS did not induce any significant increase in the number of revertant colonies for any of the tester strains in the presence or absence of induced rat liver S9. | There is no in vitro evidence of PFBS mutagenicity. | Pant (2001)
Genotoxicity test | Human hepatoma (HepG2) cells were treated with 0.4 μM to 2 mM PFBS. Intracellular ROS production was measured by use of 2′,7′-dichlorofluorescein diacetate and DNA damage was measured with the comet assay. | The amount of ROS and DNA strand breaks remained unaffected by PFBS treatment. | PFBS did not generate ROS or DNA damage in human liver cells. | Eriksen et al. (2010)
CHO chromosomal aberration | Cultures of CHO cells were treated with K^+^PFBS at concentrations ranging from 0 to 5,000 μg/mL with or without exogenous metabolic activation. The in vitro exposure duration was 3 hr. | PFBS did not induce a statistically significant increase in the percentage of cells with aberrations at any of the concentrations tested, either with or without metabolic activation, in either assay when compared to the solvent controls. | Based on the negative results in the in vitro CA assay in CHO cells, PFBS is not considered to be a clastogenic agent. | Xu (2001)
Micronucleus assay | Male and female S-D rats (5/group) were exposed twice daily to K^+^PFBS by gavage at doses of 31.3, 62.5, 125, or 250 mg/kg for 28 d. | PFBS did not induce a statistically significant increase in the frequency of micronucleated polychromatic erythrocytes. | PFBS was negative for micronuclei in the blood of male and female rats, indicating a lack of genotoxic potential. | NTP (2012)
Acute duration and other routes of exposure
Acute | 10 rats/group, young adult male rat (strain not specified), administered PFBS by gavage, single dose, 50, 100, 300, 600, or 800 μL/kg and observed for 14 d postexposure. | Mortality: 0, 20, 60, 80, and 100% at 50, 100, 300, 600, and 800 μL/kg PFBS, respectively. | Acute oral PFBS rat LD_50_ in male rats is 236 μL/kg (corresponding to 430 mg/kg). | Bomhard and Löser (1996) Low confidence (https://hawcprd.epa.gov/rob/study/100000969/)
Acute dermal | Adult (8 wk of age) male and female S-D rats (5/group) were exposed dermally (10% of body surface area) to 500, 1,000, or 2,000 mg/kg K^+^PFBS for 24 hr and then observed for 15 d postexposure for signs of clinical toxicity, mortality, BW changes, or gross pathology (terminus of study). | No treatment-related observations were noted. | PFBS is not acutely toxic via the dermal route of exposure in rats. | 3M (2000b)
Dermal irritation | Adult (14-wk of age) female NZW rabbits (3 rabbits total for study) were exposed dermally (6 cm^2^ of skin) to 500 mg K^+^PFBS for approximately 4 hr and then observed for 9 d postexposure for signs of clinical toxicity, mortality, or BW changes. | Draize scoring was performed on the patch site immediately following the exposure period and 24, 48, and 72 hr postexposure. No signs of dermal irritation were observed. No signs of clinical toxicity or mortality occurred. No treatment-related alterations in BW were noted. | PFBS did not induce erythema, edema, or other possible dermal findings during the scoring periods, indicating a lack of dermal irritant properties in rabbits. | 3M (2000a)
Ocular sensitivity | Adult (16-wk of age) female NZW rabbits (3 rabbits total for study) were exposed to approximately 80 mg K^+^PFBS via ocular installation in the left eye for 2 sec. Eyes were flushed with 0.9% saline after 24 hr and then observed and scored for up to 21 d postexposure. The rabbits were also followed for clinical signs of toxicity or mortality/moribundity. | Excessive lacrimation of the left eyes noted throughout study postexposure. Based on the laboratory scoring system, PFBS was “moderately” irritating at 24 and 72 hr postexposure. | PFBS is a moderate ocular irritant in rabbits. | 3M (2000c)
Contact hypersensitivity | Adult male (10–12 wk old) and female (9 wk old) CRL:(HA)BR Hartley guinea pigs were injected intradermally with sterile water, Freund’s adjuvant, or adjuvant containing 125 mg/mL K^+^PFBS (induction phase). D 7 after induction, a petrolatum paste containing 0.5 g K^+^PFBS was applied to the previous injection site of the guinea pigs for 48 hr (topical induction phase). D 22, a challenge dose of 0.5 g K^+^PFBS (petrolatum paste) was applied to the shaved left cranial flank (right flanks were treated with petrolatum paste only) (challenge phase). This challenge procedure was repeated on D 29. Challenge sites were observed and scored following each challenge period (D 24–25 males and females and D 31–32 males only). Guinea pigs were also followed for signs of clinical toxicity, mortality/moribundity, or alterations in BW. | No mortalities, clinical signs of toxicity, or changes in BW associated with PFBS exposure were noted. Dermal scores were zero (no response) in females and did not exceed 1 in males (discreet or patchy edema), which was not considered significant compared with control guinea pigs exposed to Freund’s adjuvant alone. | PFBS is not considered an allergen in the guinea pig maximization test. | 3M (2002a)

BW = body weight; CA = chromosomal aberration; CHO = Chinese hamster ovary; DNA = deoxyribonucleic acid; K^+^PFBS = potassium perfluorobutane sulfonate; LD_50_ = median lethal dose; NZW = New Zealand White; PFBS = perfluorobutane sulfonic acid; ROS = reactive oxygen species; S-D = Sprague-Dawley.

### 4.8.1 Tests Evaluating Genotoxicity and Mutagenicity

Genotoxic, mutagenic, and clastogenic effects of PFBS have been tested in mammalian and prokaryotic cells in vitro (Eriksen et al., 2010; NTP, 2005; Pant, 2001; Xu, 2001), and in rats in vivo (NTP, 2019). PFBS was negative for mutagenicity in Escherichia coli strain pKM101 and Salmonella typhimurium strain TA100 (NTP, 2005). Mutagenicity test results were equivocal in S. typhimurium strain TA98. Pant (2001) tested PFBS at concentrations up to 5,000 μg/plate in E. coli strain WP2uvrA and S. typhimurium strains TA98, TA100, TA1535, and TA1537 in the presence or absence of exogenous metabolic activation and found no evidence of mutagenic activity. In mammalian cells in vitro, PFBS did not generate reactive oxygen species (ROS) or oxidative deoxyribonucleic acid damage in HepG2 cells (Eriksen et al., 2010). PFBS also failed to induce chromosomal aberrations in Chinese hamster ovary cells, suggesting a lack of clastogenic activity (Xu, 2001). Adult male and female S-D rats exposed twice daily to oral PFBS at doses up to 250 mg/kg for 28 days did not experience any significant increases in micronucleated polychromatic erythrocytes, indicating a lack of genotoxic activity (see Table 5) (NTP, 2012).

### 4.8.2 Acute Duration and Other Routes of Exposure

Limited data are available to evaluate acute toxicity and effects from dermal exposure to PFBS (see Table 5). One low-confidence acute oral toxicity study on male rats administered PFBS by gavage reported a median lethal dose (LD_50_) of 236 μL/kg (corresponding to 430 mg/kg) (Bomhard and Löser, 1996). One acute dermal toxicity study concluded that PFBS is not acutely toxic via the dermal route of exposure in rats, with no treatment-related observation at doses up to 2,000 mg/kg (3M, 2000b). PFBS was not reported to induce erythema, edema, or other possible dermal findings during the scoring periods, indicating a lack of dermal irritant properties in rabbits exposed to 500 mg K^+^PFBS for approximately 4 hours (3M, 2000a). PFBS was found to be a moderate ocular irritant in rabbits exposed to 80 mg K^+^PFBS via ocular installation (3M, 2000c). PFBS did not induce skin sensitization in the guinea pig maximization test with an intradermal injection of 125 mg/mL and topical induction of 0.5 g K^+^PFBS (3M, 2002a).

10 A marker of delayed reproductive development (Foster and Gray, 2013; U.S. EPA, 1996b).