# 3.0 OVERVIEW OF EVIDENCE IDENTIFICATION FOR SYNTHESIS AND DOSE-RESPONSE ANALYSIS

## 3.1 LITERATURE SEARCH AND SCREENING RESULTS

The database searches yielded 451 unique records, with 50 records identified from additional sources, such as TSCA submissions, posted NTP study tables, peer-review recommendations, and review of reference lists from other authoritative sources. Of the 501 studies identified, 377 were excluded during title and abstract screening, 124 were reviewed at the full-text level, and 42 were considered relevant to the PECO eligibility criteria (see Figure 4). This included 19 epidemiologic studies (described in 22 publications), 10 in vivo animal studies (described in 15 peer-reviewed and non-peer-reviewed publications), and 5 in vitro genotoxicity studies. The detailed search approach, including the query strings and PECO criteria, is provided in Appendix A and Appendix B, respectively.

Figure 4 Literature Search and Screening Flow Diagram for PFBS (CASRN 375-73-5)

## 3.2 STUDY EVALUATION RESULTS

Based on the study evaluations, seven human epidemiology studies were considered uninformative and are not discussed any further in this assessment (see Table 4). All animal studies were considered informative and thus were identified as relevant during literature screening and included in the evidence synthesis and dose-response analysis. Overall, 12 epidemiologic studies (described in 15 publications) and 10 in vivo animal studies (described in 15 peer-reviewed and non-peer-reviewed publications) were included in the evidence synthesis and further evaluated for use in the development of toxicity values for PFBS. As shown in Figures 5 and 6, while the database of studies on PFBS is not large, several high- and medium-confidence oral exposure studies in animals were identified, as were several medium-confidence studies in humans. Multiple publications of the same study are not listed as independent studies in HAWC, they are reviewed together in one entry. In addition, Shiue (2016) was not evaluated because the outcome (i.e., sleep disturbances) was considered a nonspecific effect, and thus was not entered into HAWC. No studies were identified evaluating the toxicity of PFBS or K^+^PFBS following inhalation exposure or on the carcinogenicity of PFBS or K^+^PFBS in humans or animals.

Table 4 Epidemiological Studies Excluded Based on Study Evaluation

Reference | Outcome | Reason for Exclusion
Bao et al. (2017) | Blood pressure | Extremely poor sensitivity (96% of participants below the LOD for PFBS measurement) with no observed association.
Berk et al. (2014) | Depression | Serious concerns with temporality between exposure and outcome, confounding, and analysis.
Gyllenhammar et al. (2018) | Birth size, weight gain | Extremely poor sensitivity (median exposure = 0.01 ng/g, IQR LOD-0.04, 43% below the LOD for PFBS measurement) with no observed association.
Kim et al. (2016) | Congenital hypothyroidism | Excluded from full statistical analysis by study authors because of a high percentage below the LOD (72%) for PFBS measurement.
Seo et al. (2018) | Cholesterol, uric acid, diabetes, BMI, thyroid hormones | No consideration of potential confounding.
Shiue (2016) ^a^ | Sleep disturbances | Not evaluated because of nonspecific effect.
Wang et al. (2017) | Endometriosis-related infertility | Exposure measured concurrent with outcome for chronic outcome; serious concerns for exposure and outcome misclassification.

a Shiue (2016) was not evaluated because the outcome was sleep disturbances, which was considered a nonspecific effect, and thus was not entered in HAWC.

BMI = body mass index; HAWC = Health Assessment Workspace Collaborative; IQR = interquartile range; LOD = limit of detection; PFBS = perfluorobutane sulfonic acid.

Figure 5 Evaluation Results for Epidemiological Studies Assessing Effects of PFBS

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/visual/100000050/) for rating rationales)

Figure 5 presents a grid of study evaluation results for human epidemiological studies of PFBS. Eighteen studies are rated for participant selection, exposure measurement, outcome ascertainment, confounding, analysis, sensitivity, selective reporting, and overall confidence. Five studies were rated medium including Chen (2018), Q. Chen et al. (2019), Dong (2013), M. Huang et al. (2018), and R. Huang et al. (2019). Seven studies rated low including Qin (2016), Song (2018), Q. Yao et al. (2019), Zeng (2015), S. Zhang et al. (2018), Zhou (2016), and Zhou (2017). Lastly, six studies were as uninformative including Bao (2017), Berk (2014), Gyllenhammar (2018), Kim (2016), Seo (2018), and Wang (2017).

Figure 6 Evaluation Results for Animal Studies Assessing Effects of PFBS Exposure

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/visual/100000034/) for rating rationales)

Figure 6 is a grid of study evaluation results for animal studies. Ten studies are rated for reporting, allocation, blinding, variable control, selective reporting and attrition, exposure characterization, utility of study design, outcome assessment, results presentation, and overall confidence. All studies rated good or high in overall confidence, except two that were rated adequate or medium. Those are 3M, 2000 and Bijland, 2011.