# 2.0 PROBLEM FORMULATION

## 2.1 CONCEPTUAL MODEL

A conceptual model was developed to summarize the availability of data to understand potential health hazards related to exposure to PFBS and/or K^+^PFBS. The potential sources of these chemicals, the routes of exposure for biological receptors of concern (e.g., various human activities related to ingested drinking water, and food preparation and consumption), the potential organs and systems affected by exposure (e.g., effects such as developmental toxicity), and potential populations at risk due to exposure to PFBS and/or potassium salt are depicted in the conceptual diagram in Figure 2. Arrows indicate linkage between one or more boxes between levels of organization.

Figure 2 Conceptual Model for PFBS and/or Potassium Salt

Conceptual model presents the stressor as PFBS and the potassium salt, leading to the potential sources of exposure, which are drinking water, ambient water, industrial uses, consumer products, dust, soil, and fire-fighting foams. There is unknown potential for exposure from food and air. The possible exposure routes are oral, dermal and inhalation with data on oral exposure selected for the assessment. Limited dermal exposure data is available and unknown inhalation data. Quantitative data exists for potential thyroid, reproductive, developmental, renal, hepatic, and lipid/lipoprotein effects. Limited data exists for potential receptors in the general population being adults, children, pregnant women and fetuses, and lactating women.

## 2.2 OBJECTIVE

The overall objective of this assessment is to provide the health effects basis for the development of oral reference doses (RfDs) for PFBS (CASRN 375-73-5) and its related compound K^+^PFBS (CASRN 29420-49-3), including the science-based decisions providing the basis for identifying potential human health effects and estimating PODs. Based on the needs of the U.S. EPA partner program offices, regions, states, and/or tribes as they pertain to diverse exposure scenarios and human populations, subchronic and chronic RfDs have been derived. The assessment includes studies and information previously provided in the 2014 PPRTV assessment (U.S. EPA, 2014f) and builds upon data from the literature published since that review.

## 2.3 METHODS

### 2.3.1 Literature Search

Four online scientific databases (PubMed, Web of Science, TOXLINE, and TSCATS via TOXLINE) were searched by the U.S. EPA’s Health and Environmental Research Online (HERO) staff and stored in the HERO database.^5^ The literature search focused on chemical name and synonyms with no limitations on publication type, evidence stream (i.e., human, animal, in vitro, and in silico), or health outcomes. Full details of the search strategy for each database are presented in Appendix A. The initial database searches were conducted on July 18, 2017 and updated on February 28, 2018; May 1, 2019; and May 15, 2020. Additional studies [e.g., Lau et al. (2020); Xu et al. (2020)] were identified during subsequent review periods and integrated into the assessment as appropriate. Studies were also identified from other sources relevant to PFBS, including studies submitted to the U.S. EPA by the manufacturer of PFBS (i.e., 3M) as part of the Toxic Substances Control Act (TSCA) premanufacture notices for other PFAS chemicals or as required under TSCA reporting requirements and studies referenced in prior evaluations of PFBS toxicity (MDH, 2020; ATSDR, 2015). In addition, on March 29, 2018, the National Toxicology Program (NTP) published study tables and individual animal data from a 28-day toxicity study of PFBS (http://doi.org/10.22427/NTP-DATA-002-01134-0003-0000-4), with a protocol outlining the NTP study methods available in HERO (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/4309741) (NTP, 2011). The final NTP Technical Report on the Toxicity Studies of Perfluoroalkyl Sulfonates Administered by Gavage to Sprague-Dawley Rats was published in August, 2019 (NTP, 2019).

### 2.3.2 Screening Process

Two screeners independently conducted a title and abstract screening of the search results using DistillerSR (https://www.evidencepartners.com/products/distillersr-systematic-review-software)^6^ to identify study records that met the Population, Exposure, Comparator, and Outcome (PECO) eligibility criteria (see Appendix B for a more detailed summary):

- [underlined: Population]: Human and nonhuman mammalian animal species (whole organism) of any life stage and in vitro models of genotoxicity.
- [underlined: Exposure]: Any qualitative or quantitative estimates of exposure of PFBS or K^+^PFBS, via oral or inhalation routes of exposure. (Note: Nonoral and noninhalation studies are tracked as potential supplemental material and are presented in Section 4.8.2.)
- [underlined: Comparator]: A comparison or reference population exposed to lower levels or for shorter periods of time for humans. Exposure to vehicle-only or untreated control in animals.
- [underlined: Outcome]: Any examination of cancer or noncancer health outcomes.

In addition to the PECO criteria, the following additional exclusion criteria were applied, although these study types were tracked as supplemental material as described following the exclusion criteria:

- Records that do not contain original data such as other agency assessments, scientific literature reviews, editorials, and commentaries;
- Abstract only (e.g., conference abstracts); and
- Retracted studies.

Records that were not excluded based on title and abstract screening advanced to full-text review using the same PECO eligibility criteria. Studies that have not undergone peer review were included if the information could be made public and sufficient details of study methods and findings were included in the reports. Full-text copies of potentially relevant records identified from title and abstract screening were retrieved, stored in the HERO database, and independently assessed by the screeners using DistillerSR to confirm eligibility. At both title/abstract and full-text review levels, screening conflicts were resolved by discussion between the primary screeners in consultation with a third reviewer to resolve any remaining disagreements. During title/abstract or full-text level screening, studies that were not directly relevant to the PECO, but could provide supplemental information, were categorized (or “tagged”) by the type of supplemental information they provided (e.g., review, commentary, or letter with no original data; conference abstract; toxicokinetics; mechanistic information aside from in vitro genotoxicity studies; other routes of exposure; exposure only). Conflict resolution was not required during the screening process to identify supplemental information (i.e., tagging by a single screener was sufficient to identify the study as potential supplemental information).

### 2.3.3 Study Evaluation

Study evaluation was conducted by one reviewer for epidemiological studies and by two independent reviewers for animal studies using the U.S. EPA’s version of Health Assessment Workspace Collaborative (HAWC), a free and open source web-based software application designed to manage and facilitate the process of conducting literature assessments.^7^ For pragmatic purposes, only one reviewer was considered necessary for epidemiological studies because it was apparent during literature screening that the animal evidence would be the most informative for deriving toxicity values. The available outcomes in the epidemiological studies were heterogeneous and unrelated to each other, and only a single study was available for each outcome. This approach is consistent with recommendations from the National Academies of Science encouraging the U.S. EPA to explore ways to make systematic review more feasible, including a “rapid review in which components of the systematic review process are simplified or omitted (e.g., the need for two independent reviewers)” (NASEM, 2017). Study evaluation was not conducted for studies tagged during screening as supplemental information.

The general approach for evaluating epidemiology and animal toxicology was the same (see Figure 3), but the specifics of applying the approach differed. These evaluations were focused on the methodological approaches and completeness of reporting in the individual studies, rather than on the direction or magnitude of the study results. Evaluation of epidemiology studies was conducted for the following domains: exposure measures, outcome measures, participant selection, confounding, analysis, sensitivity, and selective reporting. For animal studies, the evaluation process focused on assessing aspects of the study design and conduct through three broad types of evaluations: reporting quality, risk of bias, and study sensitivity. A set of domains with accompanying core questions fall under each evaluation type and directed individual reviewers to evaluate specific study characteristics. For each domain evaluated for experimental animal studies (reporting quality, selection or performance bias, confounding/variable control, reporting or attrition bias, exposure methods sensitivity, and outcome measures and results display), basic considerations provided additional guidance on how a reviewer might evaluate and judge a study for that domain. Core and prompting questions used to guide the criteria and judgment for each domain are presented in Appendix C. Key concerns for the review of epidemiology and animal toxicology studies are potential sources of bias (factors that could systematically affect the magnitude or direction of an effect in either direction) and insensitivity (factors that limit the ability of a study to detect a true effect).

For each study in each evaluation domain, reviewers reached a consensus rating regarding the utility of the study for hazard identification, with categories of good, adequate, deficient, not reported, or critically deficient. These ratings were then combined across domains to reach an overall classification of high, medium, or low confidence or uninformative (definitions of these classifications are available in Appendix C). The rationale for the classification, including a brief description of any identified strengths and/or limitations from the domains and their potential impact on the overall confidence determination, is documented and retrievable in HAWC. Uninformative studies were not used in evidence synthesis or dose-response analysis. Studies were evaluated for their suitability for each health outcome investigated and could receive different ratings for each outcome.

For epidemiological studies, exposure-specific criteria were developed prior to evaluation and are described in detail in Appendix C. In brief, standard analytical methods of measurement of PFBS in serum or whole-blood using quantitative techniques such as liquid chromatograph-triple quadrupole mass spectrometry and high-pressure liquid chromatography with tandem mass spectrometry were preferred. In addition, exposure must have been assessed in a relevant time window for development of the outcome.

Figure 3 Approach for Evaluating Epidemiological and Animal Toxicology Studies

Figure 3 illustrates the approach for evaluating epidemiological and animal toxicology studies for PFBS. The approach entails three domains, individual study domain, domain judgments, and overall study rating. The individual study domain provides quality measures and metrics by which experimental animal studies or human epidemiological studies are evaluated. The individual study level evaluations then inform domain judgments ranging from critically deficient up to good. The judgments across study evaluation domains then result in an overall rating for a given study ranging from uninformative up to high.

### 2.3.4 Data Extraction

Information on study design, methods, results, and data from animal toxicology studies were extracted into the HAWC and are available at https://hawcprd.epa.gov/assessment/100000037/. Visual graphics prepared from HAWC are embedded as hyperlinks and are fully interactive when viewed online by way of a “click to see more” capability. Clicking on content allows access to study evaluation ratings, methodological details, and underlying study data. The action of clicking on content contained in those visual graphics (e.g., data points, endpoint, and study design) will yield the underlying data supporting the visual content.^8^ A HAWC user guide can be found in Appendix D. Study methods and findings from epidemiological studies were described in narratives, given the small size and heterogeneity of the evidence base. Data extraction was performed by one member of the evaluation team and checked by one to two other members. Any discrepancies in data extraction were resolved by discussion or consultation with a third member of the evaluation team. Digital rulers such as WebPlotDigitizer and Grab It! (https://automeris.io/WebPlotDigitizer/ and https://grab-it.soft112.com/, respectively) were used to extract numerical information from figures. Use of digital rulers was documented during extraction. Dose levels were extracted as reported in the study and converted to mg/kg-day (HED) for endpoints that were considered for use in the dose-response and derivation of toxicity values.

### 2.3.5 Evidence Synthesis

For the purposes of this assessment, after study evaluation, the informative evidence for each outcome was summarized from the available human studies and, separately, the available animal studies. This synthesis provides a short synopsis of the breadth of data available to inform each outcome and summarizes information on the general study design, doses tested, outcomes evaluated, and results for the endpoints of interest within each study. While the evidence synthesis describes inferences about the methodological rigor and sensitivity of the individual studies (i.e., study confidence) and discusses the pattern and magnitude of the experimental findings within studies, it does not include conclusions drawn across the sets of studies (see “Evidence Integration and Hazard Characterization,” next).

### 2.3.6 Evidence Integration and Hazard Characterization

In this assessment, the evaluation of the available evidence from informative human and animal studies was described in an evidence integration narrative for each outcome, including overall evidence integration judgments as to whether the data provide evidence sufficient to support a hazard. These integrated judgments serve to characterize the extent of the available evidence for each outcome, including information on potential susceptible populations and life stages, as well as important uncertainties in interpreting the data.

The evidence integration for each health effect considered aspects of an association that might suggest causation first introduced by Austin Bradford Hill (Hill, 1965), including the consistency, exposure-response relationship, strength of association, biological plausibility, and coherence of the evidence. This involved weighing the PFBS-specific human and animal evidence relating to each of these considerations within or across studies, including both evidence that supports causation as well as evidence that indicates lack of support. For example, the evaluation of consistency examined the similarity of results across studies (e.g., direction and magnitude). When inconsistencies across studies were identified, the evaluation considered whether results were “conflicting” (i.e., unexplained positive and negative results in similarly exposed human populations or in similar animal models) or “differing” (i.e., mixed results explained by differences between human populations, animal models, exposure conditions, or study methods), based on analyses of potentially important explanatory factors such as confidence in the studies’ results (the results of higher confidence studies were emphasized), exposure levels or duration, or differences in populations or species (including potential susceptible groups) across studies (U.S. EPA, 2005). While consistent evidence across studies increases support for a hazard, unexplained inconsistency or conflicting evidence decreases support for a hazard. The evaluations of these considerations were informed by U.S. EPA guidelines, including Guidelines for Developmental Toxicity Risk Assessment (U.S. EPA, 1991a) and Guidelines for Reproductive Toxicity Risk Assessment (U.S. EPA, 1996b).

The overall evidence integration judgments were developed using a structured framework based on evaluation of the considerations above (see Table 3). Using this framework, the human and animal evidence for each health effect was judged separately as supports a hazard, equivocal, or supports no hazard. Evidence integration judgments of supports a hazard span a range of supportive evidence bases that can be further differentiated by the quantity and quality of information available to rule out alternative explanations for the results. Equivocal evidence is limited in terms of the quantity, consistency, or confidence level of the available studies and serves to encourage additional research. Supports no hazard requires several high-confidence studies across potentially susceptible populations with consistent null results; this judgment was not reached in this assessment. Overall evidence integration judgments were made based on conclusions from both the animal and human data, considering the available information on the human relevance of findings in animals. Thus, for example, evidence in animals that supports a hazard alongside equivocal human evidence in the absence of information indicating that the responses in animals are unlikely to be relevant to humans would result in an overall judgment of supports a hazard for that outcome.

Table 3 Criteria for Overall Evidence Integration Judgments

| Animal | Human
Supports a hazard | The evidence for effects is consistent or largely consistent in at least one high- or medium-confidence experiment.^a^ Although notable uncertainties across studies might remain, any inconsistent evidence or remaining uncertainties are insufficient to discount the cause for concern from the positive experiments. In the strongest scenarios, the set of experiments provide evidence supporting a causal association across independent laboratories or species. In other scenarios, including evidence for an effect in a single study, the experiment(s) demonstrate additional support for causality such as coherent effects across multiple related endpoints; an unusual magnitude of effect, rarity, age at onset, or severity; a strong dose-response relationship; and/or consistent observations across exposure scenarios (e.g., route, timing, or duration), sexes, or animal strains. | One or more high- or medium-confidence independent studies reporting an association between the exposure and the health outcome. In general, the study results are largely consistent or any inconsistent results are insufficient to discount the cause for concern from the higher confidence study or studies, and there is reasonable confidence that alternative explanations, including chance, bias, and confounding, have been ruled out. In situations in which only a single study is available, the results of multiple studies are heterogeneous, or alternative explanations, including chance, bias and confounding, have not been ruled out, there is additional supporting evidence such as associations with biologically related endpoints in other human studies (coherence), large estimates of risk, or strong evidence of an exposure-response within or across studies.
Equivocal | The evidence is generally inadequate to determine hazard. This includes a lack of relevant studies available or a set of low-confidence experiments. It also includes scenarios with a set of high- or medium-confidence experiments that are not reasonably consistent or not considered informative to the hazard question under evaluation. This category would also include a single high- or medium-confidence experiment with weak evidence of an effect (e.g., changes in one endpoint among several related endpoints, and without additional evidence supporting causality). | The evidence is considered inadequate to describe an association between exposure and the health outcome with confidence. This includes a lack of studies available in humans, only low-confidence studies, or considerable heterogeneity across medium- or high-confidence studies. This also includes scenarios in which there are serious residual uncertainties across studies (these uncertainties typically relate to exposure characterization or outcome ascertainment, including temporality) in a set of largely consistent medium- or high-confidence studies.
Supports no hazard | A set of high-confidence experiments examining the full spectrum of related endpoints within a type of toxicity, with multiple species, and testing a reasonable range of exposure levels and adequate sample size in both sexes, with none showing any indication of effects. The data are compelling in that the experiments have examined the range of scenarios across which health effects in animals could be observed, and an alternative explanation (e.g., inadequately controlled features of the studies’ experimental designs) for the observed lack of effects is not available. The experiments were designed to specifically test for effects of interest, including suitable exposure timing and duration, post-exposure latency, and endpoint evaluation procedures, and to address potentially susceptible populations and life stages. | Several high-confidence studies, showing consistently null results (e.g., an OR of 1.0) ruling out alternative explanations including chance, bias, and confounding with reasonable confidence. Each of the studies should have used an optimal outcome and exposure assessment and adequate sample size (specifically for higher exposure groups and for sensitive populations). The set as a whole should include the full range of levels of exposures that human beings are known to encounter, an evaluation of an exposure response gradient, and at-risk populations and life stages and should be mutually consistent in not showing any indication of effect at any level of exposure.

a “Experiment” refers to measurements in a single population of exposed animals (e.g., a study that included separate evaluations of rats and of mice, or separate cohorts exposed at different life stages, would be considered as multiple experiments). Conversely, two papers or studies that report on the same cohort of exposed animals (e.g., examining different endpoints) would not be considered separate experiments.

OR = odds ratio.

The primary evidence and rationale supporting these decisions were summarized in a single evidence profile table to transparently convey the aspects of the evidence that were considered to increase or decrease the hazard support for each health effect. For the purposes of this assessment, only the integrated evidence that supports a hazard was considered for use in the dose-response analysis and derivation of toxicity values.

### 2.3.7 Derivation of Values

Development of the dose-response assessment for PFBS and/or the potassium salt has followed the general guidelines for risk assessment put forth by the National Research Council (NRC, 1983) and the U.S. EPA’s Framework for Human Health Risk Assessment to Inform Decision Making (U.S. EPA, 2014c). Other U.S. EPA guidelines and reviews considered in the development of this assessment include the following:

- A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002).
- A Framework for Assessing Health Risks of Environmental Exposures to Children (U.S. EPA, 2006).
- Exposure Factors Handbook (U.S. EPA, 2011a).^9^
- Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b).
- Guidance for Applying Quantitative Data to Develop Data-Derived Extrapolation Factors for Interspecies and Intraspecies Extrapolation (U.S. EPA, 2014d).
- Benchmark Dose Technical Guidance Document (U.S. EPA, 2012).
- Child-Specific Exposure Scenarios Examples (U.S. EPA, 2014a).

The U.S. EPA’s A Review of the Reference Dose and Reference Concentration Processes describes a multistep approach to dose–response assessment, including analysis in the range of observation followed by extrapolation to lower levels (U.S. EPA, 2002). As described above, before deriving toxicity values, the U.S. EPA conducted a comprehensive evaluation of available human epidemiological and animal toxicity studies to identify potential health hazards and associated dose-response information through the literature search and screening, study evaluation, evidence synthesis, and evidence integration steps. This evaluation informed the selection of candidate key studies and critical effects for dose-response analysis, from which the U.S. EPA identified a critical effect and point of departure (POD) for subchronic and chronic reference value derivation and extrapolated a selected POD to a corresponding RfD (e.g., subchronic RfD). For dose-response analysis of PFBS and/or the potassium salt, the U.S. EPA used the BMD approach to identify a POD. The steps for deriving an RfD using the BMD approach are summarized below.

- Step 1: Evaluate the data to identify and characterize endpoints related to exposure to PFBS chemicals. This step involved determining the relevant studies and adverse effects to be considered for BMD modeling. Once the appropriate data were collected, evaluated for study quality, and characterized for adverse outcomes, endpoints were selected that were judged to be relevant (i.e., for the purposes of this assessment, effects that were sufficient to support a hazard) and sensitive as a function of dose (typically defined by the no-observed-adverse-effect level [NOAEL] value). In this assessment, these decisions were directly informed by the evidence integration judgments arrived at for each assessed health outcome. Some of the most important considerations that influenced selection of endpoints for BMD modeling include data showing a dose-response relationship, percent change from controls, adversity of effect, and consistency across studies. For PFBS, thyroid, developmental, and kidney endpoints were considered for toxicity value derivations.
- Step 2: Convert the adjusted daily doses to an HED. The adjusted daily doses were converted to HEDs by considering U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b).
- Step 3: Select the benchmark response (BMR) level. The endpoints selected were modeled using the U.S. EPA’s Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). The BMR is a predetermined change in the response rate of an adverse effect. It serves as the basis for obtaining the benchmark dose lower confidence limit (BMDL), which is the 95% lower bound of the BMD. BMRs were identified and applied consistent with quantal and continuous data and, when possible, informed by understanding of biological significance.
- Step 4: BMD model the data. This step involved fitting a statistical model to the dose-response data that describes the data set of the identified adverse effect. Typically, this involved selecting a family or families of models (e.g., polynomial continuous, Hill continuous, or exponential continuous) for further consideration based on the data and experimental design. In this step, a BMDL was derived by placing confidence limits (one- or two-sided) and a confidence level (typically 95%) on a BMD to obtain the dose that ensures with high confidence that the BMR is not exceeded.
- Step 5: Determine a POD (HED). If modeling was feasible, the estimated BMDL (HED)s were used as PODs (i.e., POD [HED]). If dose-response modeling was not feasible, NOAEL (HED)s or lowest-observed-adverse-effect level (LOAEL) (HED)s were identified.
- Step 6: Provide rationale for selecting uncertainty factors. Uncertainty factors were selected in accordance with U.S. EPA guidelines considering variations in sensitivity among humans, differences between animals and humans, the duration of exposure in the key study compared to a lifetime of the species studied, and the potential limitations of the toxicology database (U.S. EPA, 2014d, 2011b, 2002, 1994).
- Step 7: Calculate the subchronic and chronic RfDs. The RfDs were calculated by dividing a POD (HED) by the selected uncertainty factors.
  RfD = (POD ( HED ))/(UF_C_) chemical structure
  where:
  - POD (HED) is calculated from the BMDL or NOAEL using a BW^3/4^ allometric scaling approach consistent with U.S. EPA guidance (U.S. EPA, 2011b)
  - UF_C_ is established in accordance with U.S. EPA guidelines (U.S. EPA, 2014d, 2011b, 2002, 1994) considering variations in sensitivity among humans, differences between animals and humans, the duration of exposure in the key study compared to a lifetime of the species studied, and the potential limitations of the toxicology database.
- Step 8: Assignment of Confidence Levels. In assessments in which an RfD or RfC is derived, characterization of the level of confidence in the principal study(ies), the database associated with that reference value, and the overall confidence in the reference value(s) are provided. Details on characterizing confidence are provided in Chapter 4 (specifically Section 4.3.9.2) of the U.S. EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994). For example, the ranking of confidence in the database (low, medium, or high) reflects EPA’s assessment of the degree to which the reference value (e.g., RfD) might potentially change (in either direction) with the acquisition of new data.

5 The U.S. EPA’s HERO database provides access to the scientific literature behind U.S. EPA science assessments. The database includes more than 2,500,000 scientific references and data from the peer-reviewed literature used by the U.S. EPA to develop its regulations.

6 DistillerSR (https://www.evidencepartners.com/products/distillersr-systematic-review-software) is a web-based systematic review software used to screen studies available at https://www.evidencepartners.com/products/distillersr-systematic-review-software.

7 HAWC: A modular web-based interface to facilitate development of human health assessments of chemicals (https://hawcproject.org/).

8 The following browsers are fully supported for accessing HAWC: Google Chrome (preferred), Mozilla Firefox, and Apple Safari. There are errors in functionality when viewed with Internet Explorer.

9 Please note that specific updates to this handbook are available at https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=236252.