# 1.0 BACKGROUND

## 1.1 PHYSICAL AND CHEMICAL PROPERTIES

Perfluorobutane sulfonic acid (PFBS) (Chemical Abstracts Service registry number [CASRN] 375-73-5)^4^ and its related salt, potassium perfluorobutane sulfonate (K^+^PFBS) (CASRN 29420-49-3), are members of the group of per- and polyfluoroalkyl substances (PFAS), more specifically the short-chain perfluoroalkane sulfonates. For purposes of this assessment, “PFBS” will signify the ion, acid, or any salt of PFBS. Concerns about PFBS and other PFAS stem from the resistance of these compounds to hydrolysis, photolysis, and biodegradation, which leads to their persistence in the environment (Sundström et al., 2012). The chemical formula of PFBS is C_4_HF_9_O_3_S and the chemical formula of K^+^PFBS is C_4_F_9_KO_3_S. Their respective chemical structures are presented in Figure 1. K^+^PFBS differs from PFBS by being associated with a potassium ion. The reported water solubility of each species suggests that in aqueous environments the sulfonate would be the predominant form. The preferential use of K^+^PFBS in laboratory studies is related to the optimal dissociation of the salt to the sulfonate (i.e., PFBS⁻) at pH values ranging from 4 to 9 (see Table 1). Table 1 provides a list of the physicochemical properties for PFBS and K^+^PFBS.

Figure 1 PFBS and K^+^PFBS Chemical Structures

Figure 1 presents the chemical structures of perfluorobutane sulfonic acid (PFBS) and its potassium salt (K-PFBS).

Table 1 Physicochemical Properties of PFBS (CASRN 375-73-5) and Related Compound K^+^PFBS (CASRN 29420-49-3)

Property (unit) | Value^a^
Property (unit) | PFBS (free acid)^b^ | K^+^PFBS (potassium salt)^c^
Boiling point (°C) | 152 | 447
Density (g/cm^3^) | 1.83 (predicted) | 1.83 (predicted)
Vapor pressure (mm Hg) | 0.104 (predicted) | 1.12 × 10^−8^
pH | ND | ND
Solubility in water (mol/L) | 0.0017 | 0.08
Molecular weight (g/mol) | 300.09 | 338.18
Dissociation constant | NA | Fully dissociated in water over the pH range of 4–9

a Values are experimentally determined unless otherwise indicated.

b U.S. EPA Chemistry Dashboard for CASRN 375-73-5 (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID5030030).

c U.S. EPA Chemistry Dashboard for CASRN 29420-49-3 (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID3037707).

K^+^PFBS = potassium perfluorobutane sulfonate; NA = not applicable; ND = no data; PFBS = perfluorobutane sulfonic acid.

## 1.2 OCCURRENCE

PFBS-based compounds are surfactants used primarily in the manufacture of paints, cleaning agents, and water- and stain-repellent products and coatings. They serve as replacements for perfluorooctane sulfonic acid (PFOS) (3M, 2002b). Various sources report detection or occurrence in environmental media and consumer products, including drinking water, ambient water, dust, carpeting and carpet cleaners, floor wax, and food packaging. To assess potential health risks associated with these occurrences, an exposure assessment, which is beyond the scope of this document, would be necessary to determine the relative source contribution to human PFBS exposure from each reported occurrence and the relevance, if any, to human health.

Oral exposure via drinking water might be expected in areas where contamination has been reported. U.S. EPA Unregulated Contaminant Monitoring Rule data for public drinking water utilities in 2013–2015 showed levels of PFBS above the minimum reporting level (>0.09 micrograms per liter [μg/L]) in water systems serving Alabama, Colorado, Georgia, the Northern Mariana Islands, and Pennsylvania (U.S. EPA, 2017; Hu et al., 2016). These utilities used both ground and surface drinking water sources, with PFBS concentrations ranging from 0.09 to 0.37 μg/L. The estimated combined number of people served by these water systems is more than 340,000 (U.S. EPA, 2018).

Measurements from 37 surface water bodies in the northeastern United States (metropolitan New York area and Rhode Island) collected in 2014 showed an 85% site detection rate (Zhang et al., 2016). PFBS has also been identified in surface waters in Georgia, New Jersey, North Carolina, and the Upper Mississippi River Basin (Post et al., 2013; Lasier et al., 2011; Nakayama et al., 2010; Nakayama et al., 2007). It has also been detected in wastewater treatment plant effluent, seawater, soil, and biosolids (Houtz et al., 2016; Zhao et al., 2012; Sepulvado et al., 2011).

PFBS contamination, which has been associated with the use of aqueous film-forming foams (AFFFs) (ESTCP, 2017; Anderson et al., 2016), was reported at Superfund sites and areas under assessment for Superfund designation. Contaminated sites include the former Wurtsmith Air Force Base, Ellsworth Air Force Base, and Dover Air Force Base (Aerostar SES LLC, 2017; Anonymous, 2017; ASTSWMO, 2015). At the Wurtsmith site, PFBS was detected at a concentration of 6.4 μg/L in groundwater contaminated by a PFAS plume originating from the fire training area (ASTSWMO, 2015). It is also present in some drinking water samples from nearby residential wells at low nanograms per liter concentrations, which were below the screening value cited by the Michigan Department of Community Health (MDCH, 2015). Other sources of PFAS and/or PFBS contamination include chrome plating operations, PFAS manufacture, and sites that use PFAS in product formulations such as textile and electronics facilities (Wang et al., 2013).

PFBS has also been detected in household dust and consumer products. There was a 92% detection frequency for PFBS among 39 household dust samples (10 from the United States) analyzed with levels ranging from 86 nanograms per gram (ng/g) for the 25th percentile to 782 ng/g for the 75th percentile (Kato et al., 2009). In a separate study, PFBS dust levels were measured in Boston area offices (n = 31), homes (n = 30), and vehicles (n = 13) with detection frequencies being relatively low—10, 3, and 0%, respectively—and ranging in the low parts per billion (Fraser et al., 2013). Consumer products could also be an exposure source. Limited quantitative testing showed the presence of PFBS in carpet and upholstery protectors (45.8 and 89.6 ng/g), carpet shampoo (25.7 and 911 ng/g), textiles (2 ng/g), and floor wax (143 ng/g) purchased in the United States (Liu et al., 2014).

PFBS is not authorized for use in food packaging. However, PFBS was detected in fast food packaging (7/20 samples) in one U.S. study (Schaider et al., 2017) although the magnitude of the detection was not reported.

The European Food Safety Authority reported the presence of PFBS in various food and drink items, including fruits, vegetables, cheese, and bottled water. For average adult consumers, the estimated exposure ranges for PFBS were 0.03–1.89 nanograms per kilogram per day (ng/kg-day) (minimum) to 0.10–3.72 ng/kg-day (maximum) (EFSA, 2012).

PFBS has been reported in serum of humans in the general population. In American Red Cross samples collected in 2015, 8.4% had a quantifiable serum PFBS concentration; the majority of samples were below the lower limit of quantitation (4.2 nanograms per milliliter [ng/mL]) (Olsen et al., 2017). The National Health and Nutrition Examination Survey (NHANES) included PFBS in consecutive biomonitoring cycles, including 2013–2014 where the 95th percentile reported for PFBS was at or below the level of detection (0.1 ng/mL). Considering the relatively rapid rate of elimination of PFBS (days to weeks), compared with longer chain PFAS (years), the lack of biomonitoring detects (e.g., NHANES 2013–2014 cycle) should not be interpreted as a lack of occurrence or exposure potential. Another study with a lower limit of detection (0.013 ng/g) reported increasing levels of PFBS in serum from primiparous nursing women in Sweden from 1996 to 2010 (Glynn et al., 2012).

## 1.3 TOXICOKINETICS

### 1.3.1 Overview

Animal evidence has shown that PFBS, like other PFAS, is well absorbed following oral administration. PFBS distributes to all tissues of the body (Bogdanska et al., 2014), but a study evaluating the volume of distribution (V_d_) concluded that distribution is predominantly extracellular (Olsen et al., 2009). Because of its resistance to metabolic degradation, PFBS is primarily eliminated unchanged in urine and feces.

Three sets of investigators have conducted toxicokinetic studies in rats and monkeys (Huang et al., 2019a; Chengelis et al., 2009; Olsen et al., 2009). Olsen et al. (2009) and Xu et al. (2020) have measured the half-life of PFBS in humans. Bogdanska et al. (2014) and Lau et al. (2020) have reported limited toxicokinetic information in mice. One study developed a physiologically based pharmacokinetic (PBPK) model that includes parameterization for PFBS (Fàbrega et al., 2015).

Results of all studies discussed in this section are summarized in Table 2.

Table 2 Summary of the Toxicokinetics of Serum PFBS (Mean ± SE)

Species/Sex | Study Design | Elimination Half-Life (hr) | AUC (μg-hr/mL) | Clearance | V_d_ (L/kg) | Reference
Mice
Mice/male | Single oral dose (30 mg/kg) | 3.7 | 1,515 | 0.019 (L/hr-kg) | 0.129 | Lau et al. (2020)
Mice/male | Single oral dose (300 mg/kg) | 6.0 | 7,178 | 0.039 (L/hr-kg) | 0.291 | Lau et al. (2020)
Mice/male | Single oral dose (combined 30/300 mg/kg) | 5.8 | | 0.038 (L/hr-kg) | 0.275 | Lau et al. (2020)
Mice/female | Single oral dose (30 mg/kg) | 4.4 | 520 | 0.056 (L/hr-kg) | 0.145 | Lau et al. (2020)
Mice/female | Single oral dose (300 mg/kg) | 4.6 | 4,587 | 0.064 (L/hr-kg) | 0.308 | Lau et al. (2020)
Mice/female | Single oral dose (combined 30/300 mg/kg) | 4.5 | | 0.063 (L/hr-kg) | 0.278 | Lau et al. (2020)
Rats
Rats/male | Single i.v. dose (10 mg/kg) | 2.1 | 254 | 0.0394 (L/hr-kg) | 0.118 | Chengelis et al. (2009)
Rats/male | Single i.v. dose (30 mg/kg) | 4.51 ± 2.22^a^ | 294 ± 77 | 119 ± 34 (mL/hr)^b^ | 0.330 ± 0.032 | Olsen et al. (2009)
Rats/male | Single oral dose (30 mg/kg) | 4.68 ± 0.43^a^ | 163 ± 10 | NA | 0.676 ± 0.055 | Olsen et al. (2009)
Rats/male | Single i.v. dose (4 mg/kg) | 4.22 ± 0.28^c^ | 116 ± 7 | 0.0345 ± 0.002 (L/hr-kg) | 0.188 ± 0.017^c^ | Huang et al. (2019a)
Rats/male | Single oral dose (4 mg/kg) | 4.89 ± 1.67^c^ | 154 ± 15 | 0.0265 ± 0.003 (L/hr-kg) | 0.174 ± 0.614^c^ | Huang et al. (2019a)
Rats/male | Single oral dose (20 mg/kg) | 5.36 ± 1.24^c^ | 533 ± 45 | 0.0376 ± 0.003 (L/hr-kg) | 0.167 ± 0.039^c^ | Huang et al. (2019a)
Rats/male | Single oral dose (100 mg/kg) | 5.25 ± 1.19^c^ | 1,320 ± 100 | 0.0755 ± 0.006 (L/hr-kg) | 0.335 ± 0.041^c^ | Huang et al. (2019a)
Rats/female | Single i.v. dose (10 mg/kg) | 0.64 | 32 | 0.311 (L/hr-kg) | 0.288 | Chengelis et al. (2009)
Rats/female | Single i.v. dose (30 mg/kg) | 3.96 ± 0.21^a^ | 65 ± 5 | 469 ± 40 (mL/hr)^d^ | 0.351 ± 0.034 | Olsen et al. (2009)
Rats/female | Single oral dose (30 mg/kg) | 7.42 ± 0.79^a^ | 85 ± 12 | NA | 0.391 ± 0.105 | Olsen et al. (2009)
Rats/female | Single i.v. dose (4 mg/kg) | 0.95 ± 0.10^c^ | 16 ± 1 | 0.252 ± 0.018 (L/hr-kg) | 0.165 ± 0.015^c^ | Huang et al. (2019a)
Rats/female | Single oral dose (4 mg/kg) | 1.50 ± 0.10^c^ | 29 ± 3 | 0.152 ± 0.020 (L/hr-kg) | 0.328 ± 0.042^c^ | Huang et al. (2019a)
Rats/female | Single oral dose (20 mg/kg) | 1.23 ± 0.12^c^ | 109 ± 23 | 0.183 ± 0.039 (L/hr-kg) | 0.326 ± 0.073^c^ | Huang et al. (2019a)
Rats/female | Single oral dose (100 mg/kg) | 1.11 ± 0.10^c^ | 387 ± 50 | 0.259 ± 0.033 (L/hr-kg) | 0.415 ± 0.063^c^ | Huang et al. (2019a)
Monkeys^b^
Cynomolgus macaque/male | Single i.v. dose (10 mg/kg) | 15 (9.65)^e^ | 1,115 ± 859 | 0.016 (L/hr-kg) | 0.209 ± 0.028 | Chengelis et al. (2009)
Cynomolgus macaque/male | Single i.v. dose (10 mg/kg) | 95.2 ± 27.1 | 24.3 ± 8.6 | 511 ± 141 (mL/hr) | 0.254 ± 0.031 | Olsen et al. (2009)
Cynomolgus macaque/female | Single i.v. dose (10 mg/kg) | 8.1 | 489 ± 180 | 0.0229 ± 0.0099 (L/hr-kg) | 0.248 ± 0.045 | Chengelis et al. (2009)
Cynomolgus macaque/female | Single i.v. dose (10 mg/kg) | 83.2 ± 41.9 | 35.4 ± 13.3 | 368 ± 120 (mL/hr) | 0.255 ± 0.017 | Olsen et al. (2009)
Humans
Males and female | Occupational (n = 6) | 619.2^f^ | NA | NA | NA | Olsen et al. (2009)
Males | Occupational (n =5) | 552^f^ | NA | NA | NA | Olsen et al. (2009)
Female | Occupational (n = 1) | 1,096.8 | NA | NA | NA | Olsen et al. (2009)
Males and females | Occupational (n = 26) | 1,056 | NA | NA | NA | Xu et al. (2020)

a Olsen et al. (2009) reported t_1/2,α_ and t_1/2,β_ in rats, presenting data for t_1/2,β_.

b Body weights were reported to be 0.200–0.250 kg (with corresponding clearance of approximately 476 mL/hr-kg).

c Huang et al. (2019a) reported t_1/2,α_, t_1/2,β_, and t_1/2_k_10_ in male rats (both oral and i.v.) and female rats (i.v. only); only t_1/2_k_10_ was reported in female rats (oral). Presenting data for t_1/2,β_ for male rats (both oral and i.v.) and female rats (i.v.) and t_1/2_k_10_ for female rats (oral). The volume of distribution (V_d_) was calculated as the sum of volume terms of the central compartment and that of the peripheral compartment except for orally exposed female rats. The volume of the peripheral compartment was not reported for orally exposed female rats, representing the volume of the central compartment only.

d The data were monitored 48 hours and 31 days postdosing for Chengelis et al. (2009) and Olsen et al. (2009), respectively.

e One male monkey had a serum concentration more than 10-fold higher than the others at 48 hours postdosing with an estimated PFBS half-life of 26 hours.

f Olsen et al. (2009) reported mean and geometric mean values for males only and all subjects, presenting data for geometric mean values.

AUC = area under the curve; i.v. = intravenous; NA = not available; PFBS = perfluorobutane sulfonic acid; SE = standard error; t_1/2_ = half-life; V_d_ = volume of distribution.

### 1.3.2 Absorption

Olsen et al. (2009) conducted intravenous (i.v.) and oral uptake studies in rats (n = 3/sex) that were given a single dose (30 milligrams per kilogram [mg/kg]) of potassium PFBS (K^+^PFBS). The serum area under the concentration curve (AUC) after i.v. administration was 294 ± 77 and 65 ± 5 (μg-hour/mL) in male and female rats, respectively, and 163 ± 10 and 85 ± 12 in males and females, respectively, after oral dosing. The large variance in AUC for male rats after i.v. dosing and greater AUC after oral dosing compared to i.v. dosing in females makes it difficult to interpret these results with certainty, but it seems that PFBS is 100% bioavailable in female rats, whereas the nominal bioavailability in male rats is only 55% based on AUC. Peak concentrations (C_max_) occurred at 0.3–0.4 hours after oral dosing, showing that absorption was fairly rapid. Bioavailability based on C_max_ was 60% in male rats and 85% in female rats, suggesting a similar sex difference as estimated from the AUCs.

The above findings are generally confirmed by Huang et al. (2019a) who found that absorption of PFBS usually occurred within 24 hours, along with the time reaching the maximal plasma concentration (T_max_) under 2.4 hours in male rats and under 1.4 hours in female rats, following a single dose of gavage administration in Hsd:Sprague-Dawley (S-D) rats (4, 20, 100 mg/kg of K^+^PFBS). However, bioavailability calculated based on the AUC after i.v. and oral doses of 4 mg/kg reported by Huang et al. (2019a) was 75% in males and 60% in females. The C_max_ values of 45% and 27% in males and females, respectively, are qualitatively the opposite of the results from Olsen et al. (2009).

Given the range of estimated bioavailability from the results of Olsen et al. (2009) and Huang et al. (2019a), a difference in this parameter between male and female rats cannot be determined. Averaging the AUC-based values for both males and females from the two studies yields an overall average of 73%.

Notably, Huang et al. (2019a) also observed that the dose-adjusted AUC decreased with increasing doses for both males and females. However, this result could be attributed to saturation of renal resorption at higher doses, rather than a reduction in absorption.

Similar observations indicating rapid absorption of PFBS have been reported for CD-1 mice orally exposed to PFBS at 30 or 300 mg/kg, where T_max_ was estimated to occur between 1 and 2 hours after gavage (Lau et al., 2020).

### 1.3.3 Distribution

PFBS has been shown to distribute to tissues within 24 hours of exposure, with the liver and kidney being the organs with highest distribution. Lau et al. (2020) evaluated the pharmacokinetic properties of PFBS in CD-1 mice at 8 weeks of age. Male and female mice were given a single dose of 0, 30, or 300 mg/kg body weight PFBS via gavage. The liver and kidneys were harvested 24 hours postdosing. PFBS distributed to both organs readily in a dose-dependent manner but did not accumulate in either organ. Lau et al. (2020) reported similar combined V_d_ values of 0.275 or 0.278 liter per kilogram [L/kg] in male and female mice, respectively (Table 2).

Olsen et al. (2009) estimated volumes of distribution for K^+^PFBS as 0.7 and 0.4 L/kg in male and female rats, respectively, and 0.25 L/kg in male and female cynomolgus macaques and concluded that K^+^PFBS is primarily distributed in the extracellular space. Consistent with the observations by Olsen et al. (2009), Huang et al. (2019a) found that the overall V_d_ for PFBS was generally comparable between male rats (0.167–0.335 L/kg) and female rats (0.165–0.415 L/kg). Chengelis et al. (2009) calculated a V_d_ of 0.248 L/kg in female cynomolgus macaques, consistent with females from Olsen et al. (2009). The male monkey V_d_ from Chengelis et al. (2009) was slightly lower (0.209 L/kg) than corresponding females and males from Olsen et al. (2009). These results indicate V_d_ is generally comparable between male and female monkeys. Huang et al. (2019a) also evaluated tissue concentrations in the liver, kidney, and brain of male and female rats and reported higher PFBS concentrations in the liver than the kidney, with the lowest concentrations occurring in the brain.

Bogdanska et al. (2014) characterized the tissue distribution of ^35^S-labeled PFBS in male C57BL/6 mice. The animals (3/group) were exposed for either 1, 3, or 5 days to an average of 16 mg of PFBS/kg-day in the diet. Following 1, 3, and 5 days of exposure, the total estimated recovery of PFBS from all tissues evaluated was 10, 5, and 3.4% of the ingested dose, respectively. The declining recovery with time reflects the lack of accumulation in tissues after the first few days, with continued elimination in the urine. The study authors suggested that these low recovery rates most likely reflect rapid excretion of PFBS and/or potentially limited uptake of the compound; however, the results of Lau et al. (2020) and Olsen et al. (2009) suggest that limited tissue distribution is also a factor.

Bogdanska et al. (2014) found that blood levels of PFBS did not change when comparing values observed after 1 and 5 days of exposure. As with PFOS, PFBS was found to distribute to most of the 20 tissues examined at all exposure durations, but the levels of PFBS were significantly lower (fivefold to 40-fold lower) than those of PFOS in tissues after similar exposure to PFOS, especially in liver and lungs (Bogdanska et al., 2014). These differences might be attributed to chain-length-dependent active transport of perfluorinated chemicals (Weaver et al., 2010). Excluding stomach and fat tissue, PFBS tissue levels increased between 1 and 3 days of exposure, but there were no significant changes in tissue levels between 3 and 5 days of exposure in any tissue examined. As with PFOS, whole bone, liver, blood, skin, and muscle accounted for approximately 90% of the recovered PFBS at all time points. The highest tissue concentrations outside of blood, however, were found in the liver, GI tissues, kidney, and cartilage. The significant total PFBS mass found in muscle and skin was due to the large total volume of these tissues rather than the per unit concentration in them. The liver contained the highest tissue concentration of PFBS at all time points, while the brain contained the lowest.

Human studies were not available on lactational transfer of PFBS. Studies are sparse pertaining to the transplacental transfer of PFBS in humans; in a Spanish mother-child paired cohort, PFBS was not found in maternal blood samples or in corresponding cord blood during the first trimester of pregnancy (Manzano-Salgado et al., 2015). However, developmental studies in animals indicate the potential for effects in offspring following gestational exposure, suggesting direct (i.e., fetus) and/or indirect (maternal/pregnant dam) effects of PFBS on offspring (Feng et al., 2017; York, 2003a, 2002).

Volume of distribution is expected to be similar across mammalian species. For PFBS, the average value for male and female monkeys (0.23 L/kg) is in the range estimated for male and female rats by Huang et al. (2019a) (0.17–0.42 L/kg), although estimates by Olsen et al. (2009) were slightly higher.

### 1.3.4 Metabolism

There is no evidence of biotransformation of PFBS. It is expected that PFBS, a short-chain (C4) of perfluoroalkyl acids (PFAAs), is metabolically inert because of the chemical stability that also exists in the longer chain PFAA chemicals, including perfluorohexane sulfonic acid (PFHxS) (C6), PFOS (C8), and perfluorooctanoic acid (PFOA) (C8).

### 1.3.5 Excretion

To facilitate comparison of differing studies for a given species, results for excretion are organized by species.

#### 1.3.5.1 Mice

Lau et al. (2020) dosed male and female CD-1 mice with 0, 30, or 300 mg/kg body weight PFBS via a single gavage dose. Trunk blood was collected at 0.5, 1, 2, 4, 8, 16, 24, and 48 hours after dosing and urine at 24 hours after dosing. Within 24 hours of dosing, more than 95% of the PFBS measured in serum was excreted into urine. Although the rate of PFBS clearance was linear with administered doses, urine accounted for only 30–43% of the original gavage doses. The half-life of PFBS was estimated to be 4.5 hours in the female mice and 5.8 hours in the males. Sex difference in PFBS elimination was also noted in that the elimination rate of absorbed PFBS was about 28% faster in female mice than male mice. Similarly, AUC estimates for the serum, kidney, and liver compartments were higher in males than in females. The findings are generally comparable to previous studies on rats (Huang et al., 2019a; Olsen et al., 2009).

#### 1.3.5.2 Rats

Chengelis et al. (2009) conducted a single-dose pharmacokinetic study in S-D rats, designed to compare the toxicokinetic behavior of PFBS with that of perfluorohexanoic acid (PFHxA), another PFAA. In this study, 12 male and 12 female rats were each administered a bolus dose of PFBS (10 mg/kg) via i.v. injection. Blood samples were collected from three animals per sex at 0.5, 1, 1.5, 2, 4, 8, and 24 hours after dosing. Additionally, to determine urinary excretion, three animals per sex were housed in metabolic cages following dose administration and their urine collected over the following time intervals: 0–6, 6–12, and 12–24 hours postdosing. Chengelis et al. (2009) fit the data to a noncompartmental model to calculate pharmacokinetic parameters. Female rats had an approximately threefold shorter mean elimination half-life of PFBS in serum (0.64 hour) than male rats (2.1 hour). This result could be in part due to the difference in clearance and V_d_. The mean apparent clearance of PFBS from the serum was approximately eightfold higher for female rats (0.311 L/hour-kg) than for male rats (0.0394 L/hour-kg), and the mean apparent V_d_ for PFBS in the serum was approximately 2.4-fold higher for female rats (0.288 L/kg) than for male rats (0.118 L/kg). Approximately 70% of the administered dose of PFBS was recovered in the urine over 24 hours postdosing regardless of sex. Using the urine data, the mean half-life values for male rats and female rats were determined to be 3.1 and 2.4 hours, respectively; the finding of longer urinary half-lives in males is consistent with those observed for serum half-lives.

Olsen et al. (2009) evaluated the elimination of PFBS in S-D rats after i.v. and oral exposure to K^+^PFBS. The terminal serum elimination half-lives following i.v. administration of 30 mg/kg K^+^PFBS were 4.51 ± 2.22 hours for males and 3.96 ± 0.21 hours for females (mean ± standard deviation [SD]). Although there was no statistically significant difference between the terminal serum half-lives in male and female rats, there was a statistically significant difference in the urinary clearance rates (p ≤ 0.01), with female rats (469 ± 40 mL/hour) having faster clearance rates than male rats (119 ± 34 mL/hour). Because clearance [CL] is calculated from the ratio of the volume of distribution [V_d_] to the half-life [t_1/2_], CL = 0.693 × V_d_ ÷ t_1/2_, differences in V_d_ can lead to differences in CL, even when t_1/2_ is similar between comparison groups. For rats receiving an oral dose, terminal serum K^+^PFBS elimination half-lives were significantly different (p ≤ 0.05) for males (t_1/2_ = 4.68 ± 0.43 hour) versus females (t_1/2_ = 7.42 ± 0.79 hour).

Huang et al. (2019a) also evaluated elimination of PFBS following a single i.v. or gavage dose in male or female Hsd:S-D rats (4, 20, 100 mg/kg of K^+^PFBS). They reported elimination half-lives (t_1/2,β_) following i.v. administration of PFBS in male and female rats of 4.22 and 0.95 hours, respectively. The data for male rats after both oral and i.v. dosing and female rats administered PFBS by i.v. fit a two-compartment model, whereas data in female rats dosed via gavage fit a one-compartment model. Thus, elimination half-lives were only reported for male rats following oral exposure and ranged from 4.89–5.36 hours. Overall plasma elimination half-lives (t_1/2_ k_10_) reported in female rats after oral administration were between 1.11–1.50 hours, approximately three to fourfold faster than in males that ranged from 4.89–5.36 hours. Similarly, clearance was three to sixfold higher in females than males given the same dose (26.5–75.5 mL/hour-kg in males, 152–259 mL/hour-kg in females).

The serum K^+^PFBS elimination half-lives reported by Huang et al. (2019a) are consistent with the findings of Olsen et al. (2009) in male rats but not in female rats. In general, the elimination half-life of serum PFBS observed by Huang et al. (2019a) in female rats was two to fourfold shorter than seen by Olsen et al. (2009). Similarly, Chengelis et al. (2009) calculated half-lives using a one compartment model for each group, whereas Olsen et al. (2009) determined separate α and β phases via a two-compartment model. Thus, the half-life estimates of Olsen et al. (2009) following i.v. administration (4.51–3.96 hours) are higher than those estimated by Chengelis et al. (2009) based on urine data (0.64-2.1 hours).

#### 1.3.5.3 Monkeys

Similar to their study in rats, Chengelis et al. (2009) investigated the toxicokinetic profile of PFBS through a series of experiments in the cynomolgus macaque (Macaca fascicularis). Monkeys (three males and three females) were each administered a bolus i.v. dose of 10 mg/kg PFBS. The controlled exposure to PFBS occurred 7 days after the same animals were each administered a bolus dose of PFHxA (10 mg/kg). Blood samples were collected at 0 hours (immediately prior to dosing) and at 1, 2, 4, 8, 24, and 48 hours after dose administration and were analyzed to determine PFBS concentration in serum. Only a single clearance half-life was estimated. The estimated half-life of PFBS in serum ranged from 5.8 to 26.0 hours in this experiment, and the median half-life was 9.55 hours for the six animals.

Olsen et al. (2009) also evaluated the elimination of PFBS (specifically, K^+^PFBS) in cynomolgus macaques after i.v. dosing. A significant difference in design from the study of Chengelis et al. (2009) is that Olsen et al. (2009) followed PFBS elimination for 31 days in monkeys (vs. 48 hours), allowing them to identify both an initial clearance half-life and a terminal-phase half-life. Olsen et al. (2009) did not observe statistically significant sex-related differences in half-life or clearance between male and female monkeys, unlike those observed in rats. In monkeys, the mean terminal serum elimination half-lives, after i.v. administration of 10 mg/kg K^+^PFBS, were 95.2 ± 27.1 hours in males and 83.2 ± 41.9 hours in females.

The serum half-life data in Olsen et al. (2009) clearly show a slow elimination phase in monkeys that does not begin until 4–10 days after dosing. Chengelis et al. (2009) followed elimination for only 48 hours, hence could not have observed this terminal clearance phase. The initial elimination half-life (t_1/2,β_) estimated by Olsen et al. (2009) in monkeys—13 hours for males, 11 hours for females—is essentially identical to the values estimated by Chengelis et al. (2009)—10 or 15 hours for males (without/with outlier) and 8 hours in females. Hence the two studies appear consistent in identifying an initial elimination half-life, but the difference in design precluded Chengelis and colleagues from identifying the longer (terminal) half-life of PFBS.

#### 1.3.5.4 Humans

In addition to their experimental studies in rats and monkeys, Olsen et al. (2009) evaluated the elimination of human serum K^+^PFBS in a group of workers with occupational exposure, with serum concentrations measured up to 180 days after cessation of further K^+^PFBS work-related activity. Given that the workers had been occupationally exposed, distribution into the tissues is expected to have been complete before the observations began. The reported mean serum half-life was 23 days in males (n = 5) and 45.7 days in females (n = 1). Among the six subjects (five males, one female), the reported geometric mean serum elimination half-life for K^+^PFBS was 25.8 days (95% confidence interval [CI]: 16.6–40.2 days). Because there was only one female subject, these data cannot be used to establish a significant sex difference in elimination. Urine appeared to be a major route of elimination in humans based on observed urine levels of PFBS in the study.

Xu et al. (2020) also measured PFBS elimination in a study population with previous occupational exposure, in this case airport employees who were exposed to firefighting foam that contained PFBS. Eleven male and six female employees provided repeated blood samples during a period of observation with minimal exposure, and the data were analyzed with a linear mixed-effects pharmacokinetic model. The average half-life was 44 days (95% CI: 37–55 days). Although Xu et al. (2020) evaluated age and sex as covariates of their statistical model, they did not report either as being a significant factor for PFBS elimination. The average half-life (44 days) is larger than that reported by Olsen et al. (2009) (25.8 days), but there is significant overlap: the range of Xu et al. (2020) is 21.6–87.2 days while the range of Olsen et al. (2009) is 13.1–45.7 days.

For the sake of comparison, the linear mixed model used by Xu et al. (2020) was also applied to the estimated serum PFBS elimination half-life for the population and each individual worker (five male, one female) who manufactured K^+^PFBS, described in Olsen et al. (2009). In brief, a linear mixed effect model is an extension of simple linear models that can be used to estimate toxicokinetic parameters such as the serum elimination rate constant (k_elim_) and half-life by assuming one-compartment first-order elimination kinetics. The details of the linear mixed-effect model have been reported previously Li et al. (2018). Because of the limited sample size (only one female worker) and the lack of data on participant age for each worker in the study, age and sex were not included in the linear mixed model for reanalysis of the Olsen et al. (2009) data, whereas both were included in Xu et al. (2020). In general, the estimated half-life using the linear mixed effect model were similar to originally reported values in Olsen et al. (2009). For instance, as compared with the reported average of 25.8 days ranging from 13.1–45.7 days (Olsen et al., 2009), the estimated population elimination half-life for serum PFBS was 25.0 days with individual estimates of 14.6–42.9 days using the linear mixed effect model.

Although the estimated serum half-lives of PFBS in Olsen et al. (2009) overlapped with those of Xu et al. (2020) (mean = 43.8 days, range = 21.9–87.6 days), there is a statistically significant difference between these two studies as suggested by both parametric (one-way analysis of variance [ANOVA]) and nonparametric analyses (Kruskal-Wallis test). Overall, the estimated serum half-life of PFBS by Xu et al. (2020) is about twofold higher than Olsen et al. (2009).

Some of the difference between Xu et al. (2020) and Olsen et al. (2009) may be due to the difference in initial concentration, where the Olsen et al. (2009) subjects had initial concentrations ranging from 100–1,000 ng/mL PFBS, while the highest initial concentrations in Xu et al. (2020) was 1.3 ng/mL. It is possible that the higher serum levels in the Olsen et al. (2009) subjects resulted in saturation of renal resorption, hence more rapid excretion/shorter half-lives. However, to the extent that some ongoing low-level exposure occurred during the period of observation, such exposure would cause a greater bias towards over-estimation of the elimination half-life for the Xu et al. (2020) subjects than those of Olsen et al. (2009). The data of Olsen et al. (2009) might also have a greater signal:noise ratio than the data of Xu et al. (2020). Despite this uncertainty, the fact that the blood concentrations of the Xu et al. (2020) are more representative of environmental exposure, that their sample size was larger, and a significant statistical difference was observed, the two data sets will not be combined and the half-life estimated by Xu et al. (2020) is presumed to better predict human dosimetry at environmental levels.

The possibility that menstrual blood loss could contribute to overall clearance was evaluated, assuming that the concentration of PFBS in menstrual blood is the same as in the general circulation and that the V_d_ in humans is equal to the average value estimated for monkeys (0.23 L/kg). The results indicate that this avenue of loss is more than two orders of magnitude slower than that indicated by the measured PFBS half-life in humans. Thus, menstrual blood loss is unlikely to contribute significantly to overall PFBS elimination.

### 1.3.6 Physiologically Based Pharmacokinetic Models

Fàbrega et al. (2015) developed a physiologically based pharmacokinetic model to estimate the concentration of PFAS, including PFBS, in human tissues based on an existing model and experimental data on concentrations of PFAS in human tissues from individuals in Catalonia, Spain. Several uncertainties in the model limit the use for this assessment of PFBS.

There are three chemical-specific parameters that determine the rate of elimination: the free fraction in blood, the maximum rate of resorption in the kidney (T_m_), and the saturation constant for that resorption (K_t_). No details beyond a rough description are provided on how these parameter values were identified. The data used for calibration are population samples in adults, who would essentially be at steady state, and only a single average level of exposure and corresponding blood concentration are reported, precluding the possibility of evaluating exposure or concentration dependence. In this situation it is not possible to uniquely identify the three parameters. This lack of identifiability is likely to be an underlying cause of the extreme variability in the individual parameter values (among the 11 PFAS evaluated) reported by Fàbrega et al. (2015).

In addition, the rate constant for elimination from the glomerular filtrate compartment to the urine “storage” compartment (i.e., the bladder) is the total glomerular filtration rate (GFR), which is approximately 10 L/hour in a 70 kg adult. But most of the glomerular flow is resorbed in the nephrons, and human urinary output is less than 2 L/day. Hence, the use of GFR for elimination is not realistic. Finally, note that while the model structure and the equations listed by Fàbrega et al. (2015) appear to be appropriate for most humans, excretion via lactation is not included.

Of considerable concern is the way in which partition coefficients (PCs) were identified. In particular, PCs were obtained by taking tissue concentration data from cadavers and comparing those to average blood concentrations from volunteer subjects, albeit from the same geographical area (county in Spain). The liver:blood PC for PFDA was thereby estimated to be 0.001 while the value for PFNA was 1.65. By contrast, Kim et al. (2019) obtained values of ~0.6–0.7 for PFDA in male and female rats, ~1.2 for PFNA in male rats, and ~0.5 for PFNA in female rats. Thus, there seems to be extreme inconsistency and hence uncertainty in these parameters as estimated by Fàbrega et al. (2015). Generally, human PCs should have values similar to those in rats.

The study authors do not compare model predictions for Tarragona County, Spain, with measured values for county residents (i.e., the data used for model calibration). Also, the study authors state that 20–30 years of simulated time are required to reach steady state. These steady-state estimates are inconsistent with the elimination data from Olsen et al. (2009), in which the half-life in males was 24 days, and in one female subject 46 days. These empirical half-lives are consistent with a time to steady state of less than a year, indicating that the predicted clearance from Fàbrega et al. (2015) may be an order of magnitude or more too low. At the same time, the simulated levels of five PFAS (average levels) were consistently lower than the averages in the validation data, four of these being lower by an order of magnitude or more.

Thus, predictions of the Fàbrega et al. (2015) model are considered highly uncertain, and data other than those used by the study authors will be needed to accurately estimate key pharmacokinetic (PK) parameters for PFBS and these other PFAS, a task that would require significant additional research.

### 1.3.7 Summary

Collectively, elimination half-lives appear to be similar for mice and rats, with potential sex-specific toxicokinetic differences being reported (i.e., females appearing to have a faster elimination rate). Humans have a longer serum elimination half-life (~weeks) than both rodents (~hours) and monkeys (~days). Further, although V_d_ information is not available for humans, observations in male and female mice, rats, and monkeys exposed to comparable doses indicate comparability across species. Results of all studies discussed in this section are summarized in Table 2.

4 The CASRN given is for linear PFBS; the source PFBS used in toxicity studies was assayed at ≥98% linear, suggesting some minor proportion of other chemicals, such as branched PFBS isomers, are present. Thus, observed health effects may apply to the total linear and branched isomers in a given exposure source.