# EXECUTIVE SUMMARY

## SUMMARY OF OCCURRENCE AND HEALTH EFFECTS

The U.S. Environmental Protection Agency (U.S. EPA) is issuing subchronic and chronic oral toxicity values for perfluorobutane sulfonic acid (PFBS) (Chemical Abstracts Service registry number [CASRN] 375-73-5) and its related salt, potassium perfluorobutane sulfonate (K^+^PFBS) (CASRN 29420-49-3). The ionic state of per- and polyfluoroalkyl substances (PFAS) such as PFBS influence physicochemical properties such as water or lipid solubility and bioaccumulative potential, which in turn impact fate and transport in the environment and potential human health and ecological effects in exposed populations. K^+^PFBS fully dissociates in aqueous solutions with pH levels ranging from 4–9; thus, the oral toxicity values derived in this document are also applicable to the deprotonated anionic form of PFBS (i.e., PFBS^–^; CASRN 45187-15-3).

The toxicity assessment for PFBS includes toxicity values associated with potential noncancer health effects following oral exposure (in this case, oral reference doses [RfDs]). This assessment evaluates human health hazards. The toxicity assessment and the values contained within is not a risk assessment because it does not include an exposure assessment nor an overall risk characterization. Further, the toxicity assessment does not address the legal, political, social, economic, or technical considerations involved in risk management. The PFBS toxicity assessment can be used by U.S. EPA, states, tribes, and local communities, along with specific exposure and other relevant information, to determine, under the appropriate regulations and statutes, if, and when, it is necessary to take action to address potential risk associated with human exposures to PFBS.

PFBS and K^+^PFBS are both four-carbon, fully fluorinated alkane members of a large and diverse class of linear and branched compounds known as “per- and polyfluoroalkyl substances,” or PFAS. In the early 2000s, concerns grew over the environmental persistence, bioaccumulation potential, and long half-lives in humans of longer chain PFAS, in particular, perfluorooctanoic acid (PFOA) and perfluorooctane sulfonic acid (PFOS). As a result, shorter chain PFAS such as PFBS were developed and integrated into various consumer products and industrial applications, because PFBS has the desired properties and characteristics associated with this class of compounds but with faster elimination from the body than PFOA and PFOS. PFBS is associated with aqueous film-forming foam (foams (AFFFs) and used during chrome electroplating as a mist suppressant (See Section 1.2). It has also been found in food contact materials, dust, and source and finished drinking water. Accordingly, oral intake of water and food, inhalation, and dermal contact are plausible modes of PFBS exposure, with the oral route being the primary route of exposure. PFBS has been detected in humans, confirming exposure to this PFAS; however, the magnitude of human exposure likely depends on factors such as occupation (e.g., processing and/or manufacture of PFBS or PFBS-containing products and chrome electroplating) and living conditions (e.g., proximity to locations that make or use PFBS-containing products and nearby well-water use).

Human studies have examined possible associations between PFBS exposure and potential health outcomes such as alteration of menstruation, reproductive hormones or semen parameters, kidney function (uric acid production), lung function (induction of asthma), and lipid profile. The ability to draw conclusions about associations is limited due to the small number of human studies per outcome. Of the examined health outcomes, only asthma and serum cholesterol levels in humans were found to exhibit a statistically significant positive association with PFBS exposure. No studies have been identified that evaluate the association between PFBS exposure and potential cancer outcomes. While the epidemiology studies were not influential to drawing evidence integration judgments or the derivation of toxicity values, the general findings identify potential areas of future research.

Animal studies of repeated-dose PFBS exposure have been exclusively via the oral route, used the potassium salt of PFBS (K^+^PFBS) as the source exposure material, and have examined noncancer effects only. The available rat and mouse studies support identification of thyroid, developmental, and kidney endpoints as potential health effects following repeated exposures in utero and/or during adulthood. Animal studies have also evaluated other health outcomes, such as liver effects, reproductive parameters, lipid/lipoprotein homeostasis, and effects on the spleen and hematology; however, the available evidence does not support a clear association with PFBS exposure and these outcomes.

### Noncancer Effects Observed Following Oral Exposure

Oral exposures to PFBS or its K^+^ salt in adult and developing rats and mice have been shown to result in thyroid, developmental, and kidney effects. Thyroid effects in exposed adult rats and mice and in developing mice were primarily expressed through significant decreases in circulating levels of hormones such as thyroxine (T_4_) and triiodothyronine (T_3_). In early developmental life stages in mice (e.g., newborn), decreases in thyroid hormone were accompanied by other effects indicative of delayed maturation or reproductive development (e.g., vaginal patency and eyes opening). Kidney weight and/or histopathological alterations (e.g., renal tubular and ductal epithelial hyperplasia) were observed in rats following short-term and subchronic oral exposures. Many of the kidney effects, however, occurred at higher doses than did the thyroid and developmental effects. The limited number of human studies examining oral PFBS exposure does not inform the potential for effects in thyroid, developing offspring, or the renal system.

### Oral Reference Doses for Noncancer Effects

Subchronic^1^ and chronic^2^ oral RfDs were derived for PFBS. The hazards of potential concern include thyroid, developmental, and kidney effects. From these identified targets of PFBS toxicity, perturbation of thyroid hormone levels (e.g., T_4_) was used as the critical effect for deriving a subchronic and chronic RfD. Based on recommendations in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b), chemical-specific toxicokinetic data (e.g., serum half-lives) were used to scale a toxicologically equivalent dose of orally administered PFBS from animals to humans. Following the U.S. EPA’s Benchmark Dose Technical Guidance Document (U.S. EPA, 2012), benchmark dose (BMD) modeling of thyroid effects in a developmental life stage following exposure to K^+^PFBS in utero resulted in a BMDL_0.5SD_ human equivalent dose (HED) of 0.095 milligrams per kilogram per day (mg/kg-day). This HED associated with thyroid effects served as the point of departure (POD) for deriving the subchronic and chronic RfDs.

The subchronic RfD for K^+^PFBS was calculated by dividing the POD (HED) for decreased serum total T_4_ observed in newborn (Postnatal Day [PND] 1) mice, in the study conducted by Feng et al. (2017), by a composite uncertainty factor (UF_C_) of 100 to account for extrapolation from mice to humans (an interspecies uncertainty factor, or UF_A_, of 3), for interindividual differences in human susceptibility (intraspecies uncertainty factor, or UF_H_, of 10), and for deficiencies in the toxicity database (database uncertainty factor, or UF_D_, of 3) (a value of 1 was applied for subchronic-to-chronic UF, or UF_S_, and LOAEL-to-NOAEL uncertainty factor, or UF_L_) (see Table 10), yielding a subchronic RfD of 0.00095 mg/kg-day rounded to 1 × 10^−3^ mg/kg-day. Because K^+^PFBS is fully dissociated in water at the environmental pH range of 4–9 to the PFBS anion (PFBS^−^) and the K^+^ cation, data for K^+^PFBS were used to derive a subchronic RfD for the free acid (PFBS) by adjusting for differences in molecular weight (MW) between K^+^PFBS (338.19) and PFBS (300.10), yielding the value of 0.00085 mg/kg-day rounded to 9 × 10^−4^ mg/kg-day for the subchronic RfD for PFBS (free acid).

The chronic RfD for K^+^PFBS associated with thyroid effects was calculated by dividing the POD (HED) for decreased serum total T_4_ observed in newborn (PND 1) mice, in the study conducted by Feng et al. (2017), by a UF_C_ of 300 to account for extrapolation from mice to humans (UF_A_ of 3), for interindividual differences in human susceptibility (UF_H_ of 10), and deficiencies in the toxicity database (UF_D_ of 10) (a value of 1 was applied for UF_S_ and UF_L_) (see Table 12), yielding a chronic RfD of 0.00032 mg/kg-day rounded to 3 × 10^−4^ mg/kg-day. Like the subchronic RfD for thyroid effect, based on the data for K^+^PFBS, a chronic RfD for PFBS (free acid) of 0.00028 mg/kg-day rounded to 3 × 10^−4^ mg/kg-day was derived.

### Confidence in the Oral RfDs

The overall confidence in the subchronic RfD for thyroid effects is medium. The gestational exposure study conducted by Feng et al. (2017) reported administration of K^+^PFBS by gavage in pregnant Institute of Cancer Research (ICR) mice (10/dose) from Gestation Days (GDs) 1 to 20. This study was of good quality (i.e., high confidence) with adequate reporting and consideration of appropriate study design, methods, and conduct (click to see risk of bias analysis (https://hawcprd.epa.gov/rob/study/100000968/) in HAWC^3^). Confidence in the oral toxicity database for derivation of the subchronic RfD is medium because, although there are multiple short-term studies and a subchronic-duration toxicity study in laboratory animals, a two-generation reproductive toxicity study in rats (Lieder et al., 2009b), and multiple developmental toxicity studies in mice and rats, there are no PFBS studies available that have specifically evaluated health effect domains of emerging concern across the PFAS class such as immunotoxicity and mammary gland development (Dewitt et al., 2012; White et al., 2007). Further, neurodevelopmental effects are of particular concern when perturbations in thyroid hormone occur during a sensitive early life stage, and the absence of a study evaluating neurodevelopmental effects following PFBS exposure is a source of uncertainty in the assessment.

The overall confidence in the chronic RfD for thyroid effects is low. Although the chronic RfD, like the subchronic RfD, was derived using data from the high-confidence principal study conducted by Feng et al. (2017), there is increased concern about the potential for identification of hazards following longer (i.e., chronic) duration PFBS exposures. In addition, because of the lack of studies that specifically evaluated health effect domains of emerging concern across the PFAS class, such as immunotoxicity, mammary gland development, or neurodevelopmental at any exposure duration—but particularly for chronic duration—confidence in the database specifically for a chronic RfD is low.

### Effects Other Than Cancer Observed Following Inhalation Exposure

There are no studies available that examined toxicity in humans or experimental animals following inhalation exposure, thereby precluding the derivation of an inhalation reference concentration (RfC).

### Evidence for Carcinogenicity

Under the U.S. EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005), the Agency concluded that there is “Inadequate Information to Assess Carcinogenic Potential” for PFBS and K^+^PFBS by either oral or inhalation routes of exposure. Therefore, the lack of data on the carcinogenicity of PFBS and the related compound K^+^PFBS precludes the derivation of quantitative estimates for either oral (oral slope factor) or inhalation (inhalation unit risk) exposure.

1 Subchronic exposure: Repeated exposure by the oral, dermal, or inhalation route for more than 30 days, up to approximately 10% of the lifespan in humans (more than 30 days up to approximately 90 days in typically used laboratory animal species).

2 Chronic exposure: Repeated exposure by the oral, dermal, or inhalation route for more than approximately 10% of the lifespan in humans (more than approximately 90 days to 2 years in typically used laboratory animal species). (https://ofmpub.epa.gov/sor_internet/registry/termreg/searchandretrieve/glossariesandkeywordlists/search.do?details=&glossaryName=IRIS%20Glossary#formTop)

3 HAWC: A modular web-based interface to facilitate development of human health assessments of chemicals; see Appendix D for details.