# APPENDIX H REFERENCES

3M (3M Company). (2000a). Acute dermal irritation study of T-7485 applied to New Zealand white rabbits. (Study Number: 132-004). St. Paul, MN: 3M Corporate Toxicology.
3M (3M Company). (2000b). Acute dermal toxicity study of T-7485 applied to Sprague-Dawley rats. (Study Number: 132-010). St. Paul, MN: 3M Corporate Toxicology.
3M (3M Company). (2000c). Acute ocular irritation study of T-7485 applied to New Zealand white rabbits. (Study Number: 132-005). St. Paul, MN: 3M Corporate Toxicology.
3M (3M Company). (2000d). A repeated dose range-finding toxicity study of T-7485 in Sprague-Dawley rats. (Study Number: 132-006). St. Paul, MN: 3M Pharmaceuticals.
3M (3M Company). (2001). A 28-day oral (gavage) toxicity study of T-7485 in Sprague-Dawley rats. (Study Number: 132-007). St. Paul, MN: 3M Corporate Toxicology.
3M (3M Company). (2002a). Delayed contact hypersensitivity study of T-7485 in Hartley guinea pigs (maximization test). (Study Number: 132-015). St. Paul, MN: 3M Corporate Toxicology.
3M (3M Company). (2002b). Environmental, health, safety, and regulatory (EHSR) profile of perfluorobutane sulfonate (PFBS). : http://multimedia.3m.com/mws/media/172303O/ehsr-profile-of-perfluorobutane-sulfonate-pfbs.pdf
3M (3M Company). (2010). TSCA 8(e) substantial risk notice: Sulfonate-based and carboxylic-based fluorochemicals, docket 8EHQ-0598-373 - Results from a mechanistic investigation of the effect of PFBS, PFHS, and PFOS on lipid and lipoprotein metabolism in transgenic mice [TSCA Submission]. (8EHQ-10-00373DH). St. Paul, MN.
Aerostar SES LLC. (2017). Final site inspection report of fire fighting foam usage at Dover Air Force Base, Kent County, Delaware.
Alexander, EK; Pearce, EN; Brent, GA; Brown, RS; Chen, H; Dosiou, C; Grobman, W; Laurberg, P; Lazarus, JH; Mandel, SJ; Peeters, R; Sullivan, S. (2017). 2017 Guidelines of the American Thyroid Association for the diagnosis and management of thyroid disease during pregnancy and the postpartum. Thyroid 27: 315–389. 10.1089/thy.2016.0457 28056690
Andersen, SL; Andersen, S; Liew, Z; Vestergaard, P; Olsen, J. (2018). Maternal Thyroid Function in Early Pregnancy and Neuropsychological Performance of the Child at 5 Years of Age. J Clin Endocrinol Metab 103: 660–670. 10.1210/jc.2017-02171 29220528
Anderson, RH; Long, GC; Porter, RC; Anderson, JK. (2016). Occurrence of select perfluoroalkyl substances at U.S. Air Force aqueous film-forming foam release sites other than fire-training areas: Field-validation of critical fate and transport properties. Chemosphere 150: 678–685. 10.1016/j.chemosphere.2016.01.014 26786021
Anonymous. (2017). Final technical memorandum proposed groundwater monitoring well locations perfluorinated compound delineation, areas of concern perfluorinated compound-1. Ellsworth Air Force Base, South Dakota. Anonymous.
ASTSWMO (Association of State and Territorial Solid Waste Management Officials). (2015). Perfluorinated chemicals (PFCS): Perfluorooctanoic acid (PFOA) & perfluorooctane sulfonate (PFOS) information paper.
ATSDR (Agency for Toxic Substances and Disease Registry). (2009). Draft toxicological profile for perfluoroalkyls. Agency for Toxic Substances and Disease Regristry. http://www.atsdr.cdc.gov/toxprofiles/tp200.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2015). Draft toxicological profile for perfluoroalkyls. https://www.atsdr.cdc.gov/toxprofiles/tp200.pdf
Bao, J; Lee, YL; Chen, PC; Jin, YH; Dong, GH. (2014). Perfluoroalkyl acids in blood serum samples from children in Taiwan. Environ Sci Pollut Res Int 21: 7650–7655. 10.1007/s11356-014-2594-4 24622984
Bao, WW; Qian, ZM; Geiger, SD; Liu, E; Liu, Y; Wang, SQ; Lawrence, WR; Yang, BY; Hu, LW; Zeng, XW; Dong, GH. (2017). Gender-specific associations between serum isomers of perfluoroalkyl substances and blood pressure among Chinese: Isomers of C8 Health Project in China. Sci Total Environ 607–608: 1304–1312. 10.1016/j.scitotenv.2017.07.124
Berk, M; Williams, LJ; Andreazza, A; Pasco, JA; Dodd, S; Jacka, FN; Moylan, S; Reiner, EJ; Magalhaes, PVS. (2014). Pop, heavy metal and the blues: secondary analysis of persistent organic pollutants (POP), heavy metals and depressive symptoms in the NHANES National Epidemiological Survey. BMJ Open 4: e005142. 10.1136/bmjopen-2014-005142
Bijland, S; Rensen, PCN; Pieterman, EJ; Maas, ACE; van der Hoorn, JW; van Erk, MJ; Havekes, LM; Willems van Dijk, K; Chang, SC; Ehresman, DJ; Butenhoff, JL; Princen, HMG. (2011). Perfluoroalkyl sulfonates cause alkyl chain length-dependent hepatic steatosis and hypolipidemia mainly by impairing lipoprotein production in APOE*3-Leiden CETP mice. Toxicol Sci 123: 290–303. 10.1093/toxsci/kfr142 21705711
Bogdanska, J; Sundstrom, M; Bergstrom, U; Borg, D; Abedi-Valugerdi, M; Bergman, A; Depierre, J; Nobel, S. (2014). Tissue distribution of S-35-labelled perfluorobutanesulfonic acid in adult mice following dietary exposure for 1-5 days. Chemosphere 98: 28–36. 10.1016/j.chemosphere.2013.09.062 24238775
Bomhard, E; Löser, E. (1996). Acute toxicologic evaluation of perfluorobutanesulfonic acid. J Am Coll Toxicol B Acute Toxic Data 15: S105. 10.1177/10915818960150S175
Calvo, R; Obregón, MJ; Escobar del Rey, F; Morreale de Escobar, G. (1992). The rat placenta and the transfer of thyroid hormones from the mother to fetus: Effects of maternal thyroid status. Endocrinology 131: 357–365.1612015
Casey, BM; Thom, EA; Peaceman, AM; Varner, MW; Sorokin, Y; Hirtz, DG; Reddy, UM; Wapner, RJ; Thorp, JM; Saade, G; Tita, AT; Rouse, DJ; Sibai, B; Iams, JD; Mercer, BM; Tolosa, J; Caritis, SN; VanDorsten, JP. (2017). Treatment of subclinical hypothyroidism or hypothyroxinemia in pregnancy. N Engl J Med 376: 815–825. 10.1056/NEJMoa1606205 28249134
CDC (Centers for Disease Control and Prevention). (2009). Fourth national report on human exposure to environmental chemicals. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport/
CDC (Centers for Disease Control and Prevention). (2018). National report on human exposure to environmental chemicals. Updated tables, March 2018. Atlanta, GA: U.S. Department of Health and Human Services. https://www.cdc.gov/exposurereport/
Chen, Q; Huang, R; Hua, L; Guo, Y; Huang, L; Zhao, Y; Wang, X; Zhang, J. (2018). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and childhood atopic dermatitis: A prospective birth cohort study. Environ Health 17: 1–12. 10.1186/s12940-018-0352-7 29301538
Chen, Q; Zhang, X; Zhao, Y; Lu, W; Wu, J; Zhao, S; Zhang, J; Huang, L. (2019). Prenatal exposure to perfluorobutanesulfonic acid and childhood adiposity: A prospective birth cohort study in Shanghai, China. Chemosphere 226: 17–23. 10.1016/j.chemosphere.2019.03.095 30908964
Chengelis, CP; Kirkpatrick, JB; Myers, NR; Shinohara, M; Stetson, PL; Sved, DW. (2009). Comparison of the toxicokinetic behavior of perfluorohexanoic acid (PFHxA) and nonafluorobutane-1-sulfonic acid (PFBS) in cynomolgus monkeys and rats. Reprod Toxicol 27: 400–406. 10.1016/j.reprotox.2009.01.013 19429410
Choksi, NY; Jahnke, GD; St Hilaire, C; Shelby, M. (2003). Role of thyroid hormones in human and laboratory animal reproductive health [Review]. Birth Defects Res B Dev Reprod Toxicol 68: 479–491. 10.1002/bdrb.10045 14745982
Corsini, E; Sangiovanni, E; Avogadro, A; Galbiati, V; Viviani, B; Marinovich, M; Galli, CL; Dell’Agli, M; Germolec, DR. (2012). In vitro characterization of the immunotoxic potential of several perfluorinated compounds (PFCs). Toxicol Appl Pharmacol 258: 248–255. 10.1016/j.taap.2011.11.004 22119708
Crissman, JW; Goodman, DG; Hildebrandt, PK; Maronpot, RR; Prater, DA; Riley, JH; Seaman, WJ; Thake, DC. (2004). Best practices guideline: Toxicologic histopathology. Toxicol Pathol 32: 126–131. 10.1080/01926230490268756 14713558
Dewitt, JC; Peden-Adams, MM; Keller, JM; Germolec, DR. (2012). Immunotoxicity of perfluorinated compounds: recent developments [Review]. Toxicol Pathol 40: 300–311. 10.1177/0192623311428473 22109712
Dong, GH; Tung, KY; Tsai, CH; Liu, MM; Wang, D; Liu, W; Jin, YH; Hsieh, WS; Lee, YL; Chen, PC. (2013a). Serum polyfluoroalkyl concentrations, asthma outcomes, and immunological markers in a case-control study of Taiwanese children. Environ Health Perspect 121: 507–513, 513e501–508. 10.1289/ehp.1205351 23309686
Dong, GH; Tung, KY; Tsai, CH; Liu, MM; Wang, D; Liu, W; Jin, YH; Hsieh, WS; Lee, YL; Chen, PC. (2013b). Serum polyfluoroalkyl concentrations, asthma outcomes, and immunological markers in a case-control study of Taiwanese children: Supplemental materials [Supplemental Data]. Environ Health Perspect 121: 1–8.23014866
EFSA (European Food Safety Authority). (2012). Perfluoroalkylated substances in food: Occurrence and dietary exposure. EFSA J 10: 2743.
Eriksen, KT; Raaschou-Nielsen, O; Sørensen, M; Roursgaard, M; Loft, S; Møller, P. (2010). Genotoxic potential of the perfluorinated chemicals PFOA, PFOS, PFBS, PFNA and PFHxA in human HepG2 cells. Mutat Res 700: 39–43. 10.1016/j.mrgentox.2010.04.024 20451658
ESTCP (Environmental Security Technology Certification Program). (2017). FAQs regarding PFASs associated with AFFF use at U.S. military sites. https://apps.dtic.mil/dtic/tr/fulltext/u2/1044126.pdf
Fàbrega, F; Kumar, V; Benfenati, E; Schuhmacher, M; Domingo, JL; Nadal, M. (2015). Physiologically based pharmacokinetic modeling of perfluoroalkyl substances in the human body. Toxicol Environ Chem 97: 814–827. 10.1080/02772248.2015.1060976
Feng, X; Cao, X; Zhao, S; Wang, X; Hua, X; Chen, L; Chen, L. (2017). Exposure of pregnant mice to perfluorobutanesulfonate causes hypothyroxinemia and developmental abnormalities in female offspring. Toxicol Sci 155: 409–419. 10.1093/toxsci/kfw219 27803384
Finken, MJ; van Eijsden, M; Loomans, EM; Vrijkotte, TG; Rotteveel, J. (2013). Maternal hypothyroxinemia in early pregnancy predicts reduced performance in reaction time tests in 5- to 6-year-old offspring. J Clin Endocrinol Metab 98: 1417–1426. 10.1210/jc.2012-3389 23408575
Fisher, DA. (1997). Fetal thyroid function: Diagnosis and management of fetal thyroid disorders. Clin Obstet Gynecol 40: 16–31.9103947
Fisher, DA; Klein, AH. (1981). Thyroid development and disorders of thyroid function in the newborn [Review]. N Engl J Med 304: 702–712. 10.1056/NEJM198103193041205 6258072
Forhead, AJ; Fowden, AL. (2014). Thyroid hormones in fetal growth and prepartum maturation [Review]. J Endocrinol 221: R87–R103. 10.1530/JOE-14-0025 24648121
Foster, P; Gray, LE, Jr. (2013). Toxic responses of the reproductive system. In CD Klaassen (Ed.), Casarett & Doull’s toxicology: The basic science of poisons (8th ed., pp. 861–906). New York, NY: McGraw-Hill Education. https://www.mheducation.com/highered/product/casarett-doull-s-toxicology-basic-science-poisons-9th-edition-klaassen/9781259863745.html
Fraser, AJ; Webster, TF; Watkins, DJ; Strynar, MJ; Kato, K; Calafat, AM; Vieira, VM; Mcclean, MD. (2013). Polyfluorinated compounds in dust from homes, offices, and vehicles as predictors of concentrations in office workers’ serum. Environ Int 60: 128–136. 10.1016/j.envint.2013.08.012 24041736
Ghassabian, A; Trasande, L. (2018). Disruption in thyroid signaling pathway: A mechanism for the effect of endocrine-disrupting chemicals on child neurodevelopment. Front Endocrinol (Lausanne) 9: 209. doi: 10.3389/fendo.2018.00204. eCollection 201829755414
Gilbert, ME. (2011). Impact of low-level thyroid hormone disruption induced by propylthiouracil on brain development and function. Toxicol Sci 124: 432–445. 10.1093/toxsci/kfr244 21964421
Gilbert, ME; Rovet, J; Chen, Z; Koibuchi, N. (2012). Developmental thyroid hormone disruption: prevalence, environmental contaminants and neurodevelopmental consequences. Neurotoxicology 33: 842–852. 10.1016/j.neuro.2011.11.005 22138353
Gilbert, ME; Sanchez-Huerta, K; Wood, C. (2016). Mild thyroid hormone insufficiency during development compromises activity-dependent neuroplasticity in the hippocampus of adult male rats. Endocrinology 157: 774–787. 10.1210/en.2015-1643 26606422
Gilbert, ME; Zoeller, RT. (2010). Thyroid hormones--impact on the developing brain: Possible mechanisms of neurotoxicity. In GJ Harry; HA Tilson (Eds.), Neurotoxicology (3rd ed., pp. 79–111). New York, NY: Informa Healthcare.
Glynn, A; Berger, U; Bignert, A; Ullah, S; Aune, M; Lignell, S; Darnerud, PO. (2012). Perfluorinated alkyl acids in blood serum from primiparous women in Sweden: serial sampling during pregnancy and nursing, and temporal trends 1996-2010. Environ Sci Technol 46: 9071–9079. 10.1021/es301168c 22770559
Grandjean, P. (2018). Delayed discovery, dissemination, and decisions on intervention in environmental health: a case study on immunotoxicity of perfluorinated alkylate substances [Editorial]. Environ Health 17: 62. 10.1186/s12940-018-0405-y 30060739
Gyllenhammar, I; Diderholm, B; Gustafsson, J; Berger, U; Ridefelt, P; Benskin, JP; Lignell, S; Lampa, E; Glynn, A. (2018). Perfluoroalkyl acid levels in first-time mothers in relation to offspring weight gain and growth. Environ Int 111: 191–199. 10.1016/j.envint.2017.12.002 29223808
Haddow, JE; Palomaki, GE; Allan, WC; Williams, JR; Knight, GJ; Gagnon, J; O’Heir, CE; Mitchell, ML; Hermos, RJ; Waisbren, SE; Faix, JD; Klein, RZ. (1999). Maternal thyroid deficiency during pregnancy and subsequent neuropsychological development of the child. N Engl J Med 341: 549–555. 10.1056/NEJM199908193410801 10451459
Hales, C; Taylor, PN; Channon, S; Paradice, R; McEwan, K; Zhang, L; Gyedu, M; Bakhsh, A; Okosieme, O; Muller, I; Draman, MS; Gregory, JW; Dayan, C; Lazarus, JH; Rees, DA; Ludgate, M. (2018). Controlled Antenatal Thyroid Screening II: Effect of Treating Maternal Suboptimal Thyroid Function on Child Cognition. J Clin Endocrinol Metab 103: 1583–1591. 10.1210/jc.2017-02378 29346569
Henrichs, J; Bongers-Schokking, JJ; Schenk, JJ; Ghassabian, A; Schmidt, HG; Visser, TJ; Hooijkaas, H; de Muinck Keizer-Schrama, SM; Hofman, A; Jaddoe, VV; Visser, W; Steegers, EA; Verhulst, FC; de Rijke, YB; Tiemeier, H. (2010). Maternal thyroid function during early pregnancy and cognitive functioning in early childhood: The generation R study. J Clin Endocrinol Metab 95: 4227–4234. 10.1210/jc.2010-0415 20534757
Hernandez, A, Fiering, S.; Martinez, E; Galton, VA; St Germain, D. (2002). The gene locus encoding iodothyronine deiodinase type 3 (Dio3) is imprinted in the fetus and expresses antisense transcripts. Endocrinology 134: 4483–4486.
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300.14283879
Hillman, NH; Kallapur, SG; Jobe, AH. (2012). Physiology of transition from intrauterine to extrauterine life. Clin Perinatol 39: 769–783.23164177
Houtz, EF; Sutton, R; Park, JS; Sedlak, M. (2016). Poly- and perfluoroalkyl substances in wastewater: Significance of unknown precursors, manufacturing shifts, and likely AFFF impacts. Water Res 95: 142–149. 10.1016/j.watres.2016.02.055 26990839
Hu, XC; Andrews, DQ; Lindstrom, AB; Bruton, TA; Schaider, LA; Grandjean, P; Lohmann, R; Carignan, CC; Blum, A; Balan, SA; Higgins, CP; Sunderland, EM. (2016). Detection of poly- and perfluoroalkyl substances (PFASs) in U.S. drinking water linked to industrial sites, military fire training areas, and wastewater treatment plants. Environ Sci Technol Lett 3: 344–350. 10.1021/acs.estlett.6b00260 27752509
Huang, M; Jiao, J; Zhuang, P; Chen, X; Wang, J; Zhang, Y. (2018). Serum polyfluoroalkyl chemicals are associated with risk of cardiovascular diseases in national US population. Environ Int 119: 37–46. 10.1016/j.envint.2018.05.051 29933236
Huang, MC; Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Granville, CA; Gibbs, ST; Blystone, CR. (2019a). Toxicokinetics of perfluorobutane sulfonate (PFBS), perfluorohexane-1-sulphonic acid (PFHxS), and perfluorooctane sulfonic acid (PFOS) in male and female Hsd:Sprague Dawley SD rats after intravenous and gavage administration. Toxicology Reports 6: 645–655. 10.1016/j.toxrep.2019.06.016 31334035
Huang, R; Chen, Q; Zhang, L; Luo, K; Chen, L; Zhao, S; Feng, L; Zhang, J. (2019b). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and the risk of hypertensive disorders of pregnancy. Environ Health 18: 5. 10.1186/s12940-018-0445-3 30626391
Hulbert, AJ. (2000). Thyroid hormones and their effects: A new perspective [Review]. Biol Rev Camb Philos Soc 75: 519–631.11117200
Julvez, J; Alvarez-Pedrerol, M; Rebagliato, M; Murcia, M; Forns, J; Garcia-Esteban, R; Lertxundi, N; Espada, M; Tardon, A; Riano Galan, I; Sunyer, J. (2013). Thyroxine levels during pregnancy in healthy women and early child neurodevelopment. Epidemiology 24: 150–157. 10.1097/EDE.0b013e318276ccd3 23232616
Kato, K; Calafat, AM; Needham, LL. (2009). Polyfluoroalkyl chemicals in house dust. Environ Res 109: 518–523. 10.1016/j.envres.2009.01.005 19261270
Kim, DH; Kim, UJ; Kim, HY; Choi, SD; Oh, JE. (2016). Perfluoroalkyl substances in serum from South Korean infants with congenital hypothyroidism and healthy infants - Its relationship with thyroid hormones. Environ Res 147: 399–404. 10.1016/j.envres.2016.02.037 26950028
Kim, SJ; Choi, EJ; Choi, GW; Lee, YB; Cho, HY. (2019). Exploring sex differences in human health risk assessment for PFNA and PFDA using a PBPK model. Arch Toxicol 93: 311–330. 10.1007/s00204-018-2365-y 30483840
Klein, AH; Oddie, TH; Parslow, M; Foley, TP; Fisher, DA. (1982). Developmental changes in pituitary-thyroid function in the human fetus and newborn. Early Hum Dev 6: 321–330. 10.1016/0378-3782(82)90070-6 6813103
Kooistra, L; Crawford, S; van Baar, AL; Brouwers, EP; Pop, VJ. (2006). Neonatal effects of maternal hypothyroxinemia during early pregnancy. Pediatrics 117: 161–167. 10.1542/peds.2005-0227 16396874
Koopdonk-Kool, JM; de Vijlder, JJ; Veenboer, GJ; Ris-Stalpers, C; Kok, JH; Vulsma, T; Boer, K; Visser, TJ. (1996). Type II and type III deiodinase activity in human placenta as a function of gestational age. J Clin Endocrinol Metab 81: 2154–2158.8964844
Korevaar, TIM; Muetzel, R; Medici, M; Chaker, L; Jaddoe, VWV; de Rijke, YB; Steegers, EAP; Visser, TJ; White, T; Tiemeier, H; Peeters, RP. (2016). Association of maternal thyroid function during early pregnancy with offspring IQ and brain morphology in childhood: A population-based prospective cohort study. Lancet Diabetes Endocrinol 4: 35–43. 10.1016/S2213-8587(15)00327-7 26497402
Lasier, PJ; Washington, JW; Hassan, SM; Jenkins, TM. (2011). Perfluorinated chemicals in surface waters and sediments from northwest Georgia, USA, and their bioaccumulation in Lumbriculus variegatus. Environ Toxicol Chem 30: 2194–2201. 10.1002/etc.622 21766321
Lau, C. (2015). Perfluorinated compounds: An overview. In JC DeWitt (Ed.), Toxicological effects of perfluoroalkyl and polyfluoroalkyl substances (pp. 1–21). New York: Springer. 10.1007/978-3-319-15518-0_1
Lau, C; Rumpler, J; Das, KP; Wood, CR; Schmid, JE; Strynar, MJ; Wambaugh, JF. (2020). Pharmacokinetic profile of Perfluorobutane Sulfonate and activation of hepatic nuclear receptor target genes in mice. Toxicology 441: 152522. 10.1016/j.tox.2020.152522 32534104
Lavado-Autric, R; Auso, E; Garcia-Velasco, JV; del Carmen Arufe, M; Escobar del Rey, F; Berbel, P; Morreale de Escobar, G. (2003). Early maternal hypothyroxinemia alters histogenesis and cerebral cortex cytoarchitecture of the progeny. J Clin Invest 111: 1073–1082. 10.1172/JCI16262 12671057
Lazarus, JH; Bestwick, JP; Channon, S; Paradice, R; Maina, A; Rees, R; Chiusano, E; John, R; Guaraldo, V; George, LM; Perona, M; Dall’Amico, D; Parkes, AB; Joomun, M; Wald, NJ. (2012). Antenatal thyroid screening and childhood cognitive function. N Engl J Med 366: 493–501. 10.1056/NEJMoa1106104 22316443
Levie, D; Korevaar, TIM; Bath, SC; Dalmau-Bueno, A; Murcia, M; Espada, M; Dineva, M; Ibarluzea, JM; Sunyer, J; Tiemeier, H; Rebagliato, M; Rayman, MP; Peeters, RP; Guxens, M. (2018). Thyroid Function in Early Pregnancy, Child IQ, and Autistic Traits: A Meta-Analysis of Individual Participant Data. J Clin Endocrinol Metab 103: 2967–2979. 10.1210/jc.2018-00224 29757392
Li, Y; Fletcher, T; Mucs, D; Scott, K; Lindh, CH; Tallving, P; Jakobsson, K. (2018). Half-lives of PFOS, PFHxS and PFOA after end of exposure to contaminated drinking water. Occup Environ Med 75: 46–51. 10.1136/oemed-2017-104651 29133598
Lieder, PH; Chang, SC; York, RG; Butenhoff, JL. (2009a). Toxicological evaluation of potassium perfluorobutanesulfonate in a 90-day oral gavage study with Sprague-Dawley rats. Toxicology 255: 45–52. 10.1016/j.tox.2008.10.002 18992301
Lieder, PH; York, RG; Hakes, DC; Chang, SC; Butenhoff, JL. (2009b). A two-generation oral gavage reproduction study with potassium perfluorobutanesulfonate (K+PFBS) in Sprague Dawley rats. Toxicology 259: 33–45. 10.1016/j.tox.2009.01.027 19428941
Liew, Z; Goudarzi, H; Oulhote, Y. (2018). Developmental exposures to perfluoroalkyl substances (PFASs): An update of associated health outcomes [Review]. Curr Environ Health Rep 5: 1–19. 10.1007/s40572-018-0173-4 29556975
Liu, X; Guo, Z; Krebs, KA; Pope, RH; Roache, NF. (2014). Concentrations and trends of perfluorinated chemicals in potential indoor sources from 2007 through 2011 in the US. Chemosphere 98: 51–57. 10.1016/j.chemosphere.2013.10.001 24268172
Mangelsdorf, I; Buschmann, J; Orthen, B. (2003). Some aspects relating to the evaluation of the effects of chemicals on male fertility [Review]. Regul Toxicol Pharmacol 37: 356–369. 10.1016/S0273-2300(03)00026-6 12758216
Manzano-Salgado, CB; Casas, M; Lopez-Espinosa, MJ; Ballester, F; Basterrechea, M; Grimalt, JO; Jiménez, AM; Kraus, T; Schettgen, T; Sunyer, J; Vrijheid, M. (2015). Transfer of perfluoroalkyl substances from mother to fetus in a Spanish birth cohort. Environ Res 142: 471–478. 10.1016/j.envres.2015.07.020 26257032
MDCH (Michigan Department of Community Health). (2015). Letter health consultation: Evaluation of drinking water near Wurtsmith Air Force Base, Oscoda, Iosco County, Michigan [Personal Communication]. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease. https://www.atsdr.cdc.gov/HAC/pha/WurtsmithAFB/WurtsmithAFB_H2O_%20LHC_09-08-2015_508.pdf
MDH (Minnesota Department of Health). (2020). Toxicological summary for: Perfluorobutane sulfonate. Minnesota Department of Health, Health Based Guidance for Water Health Risk Assessment Unit, Environmental Health Division. https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfbssummary.pdf
Min, H; Dong, J; Wang, Y; Wang, Y; Teng, W; Xi, Q; Chen, J. (2016). Maternal hypothyroxinemia-induced neurodevelopmental impairments in the progeny [Review]. Mol Neurobiol 53: 1613–1624. 10.1007/s12035-015-9101-x 25666160
Mirabella, G; Feig, D; Astzalos, E; Perlman, K; Rovet, JF. (2000). The effect of abnormal intrauterine thyroid hormone economies on infant cognitive abilities. J Pediatr Endocrinol Metab 13: 191–194.10711665
Nakayama, S; Strynar, MJ; Helfant, L; Egeghy, P; Ye, X; Lindstrom, AB. (2007). Perfluorinated compounds in the Cape Fear Drainage Basin in North Carolina. Environ Sci Technol 41: 5271–5276. 10.1021/es070792y 17822090
Nakayama, SF; Strynar, MJ; Reiner, JL; Delinsky, AD; Lindstrom, AB. (2010). Determination of perfluorinated compounds in the upper Mississippi river basin. Environ Sci Technol 44: 4103–4109. 10.1021/es100382z 20441143
NASEM (National Academies of Sciences, Engineering, and Medicine). (2017). Application of systematic review methods in an overall strategy for evaluating low-dose toxicity from endocrine active chemicals. Washington, D.C.: The National Academies Press. 10.17226/24758
Negro, R; Soldin, OP; Obregon, MJ; Stagnaro-Green, A. (2011). Hypothyroxinemia and pregnancy [Review]. Endocr Pract 17: 422–429. 10.4158/EP10309.RA 21247845
NICNAS (National Industrial Chemicals Notification and Assessment Scheme). (2005). Existing chemical hazard assessment report. Potassium perfluorbutane sulfonate. Canberra, Australia: Commonwealth of Australia, Australian Government Publishing. https://web.archive.org/web/20200503121653/http://www.nicnas.gov.au/__data/assets/pdf_file/0004/4927/Potassium_Perfluorobutane_Sulfonate_PDF.pdf (https://web.archive.org/web/20200503121653/http:/www.nicnas.gov.au/__data/assets/pdf_file/0004/4927/Potassium_Perfluorobutane_Sulfonate_PDF.pdf)
NRC (National Research Council). (1983). Risk assessment in the federal government: Managing the process. Washington, DC: National Academy Press. 10.17226/366
NTP (National Toxicology Program). (2005). Perfluorobutane sulfonate. Genetic toxicology - bacterial mutagenicity. Chemical effects in biological systems (CEBS). (Study ID A32037). Research Triangle Park, NC: National Institutes of Environmental Sciences, National Institutes of Health. http://tools.niehs.nih.gov/cebs3/ntpViews/?activeTab=detail&studyNumber=A32037
NTP (National Toxicology Program). (2011). NTP Protocol Outline of the Class Study of Perfluorinated Chemicals [perfluorobutane sulfonate (PFBS), perfluorohexane sulfonate potassium salt (PFHSKslt), perfluorooctane sulfonate (PFOS), perfluorohexanoic acid (PFHxA), perfluorooctanoic acid (PFOA), perfluorononanoic acid (PFNA), perfluorodecanoic acid (PFDA) and WY 14643 (WY)] in Harlan Sprague Dawley rats administered daily by gavage for 28-Days [NTP].
NTP (National Toxicology Program). (2012). Perfluorobutane sulfonate. Genetic toxicology - micronucleus [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Institutes of Environmental Sciences, National Institutes of Health. https://tools.niehs.nih.gov/cebs3/ntpViews/?studyNumber=002-01134-0002-0000-3
NTP (National Toxicology Program). (2015). Protocol to evaluate the evidence for an association between perfluorooctanoic acid (PFOA) or perfluorooctane sulfonate (PFOS) exposure and immunotoxicity. Department of Health and Human Services, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pfoa_pfos/protocol_201506_508.pdf
NTP (National Toxicology Program). (2016). NTP Monograph: Immunotoxicity associated with exposure to perfluorooctanoic acid (PFOA) or perfluorooctane sulfonate (PFOS) [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pfoa_pfos/pfoa_pfosmonograph_508.pdf
NTP (National Toxicology Program). (2019). NTP technical report on the toxicity studies of perfluoroalkyl sulfonates (perfluorobutane sulfonic acid, perfluorohexane sulfonate potassium salt, and perfluorooctane sulfonic acid) administered by gavage to Sprague Dawley (Hsd:Sprague Dawley SD) rats. (Toxicity Report 96). Research Triangle Park, NC. https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox096_508.pdf
Olsen, GW; Chang, SC; Noker, PE; Gorman, GS; Ehresman, DJ; Lieder, PH; Butenhoff, JL. (2009). A comparison of the pharmacokinetics of perfluorobutanesulfonate (PFBS) in rats, monkeys, and humans. Toxicology 256: 65–74. 10.1016/j.tox.2008.11.008 19059455
Olsen, GW; Mair, DC; Lange, CC; Harrington, LM; Church, TR; Goldberg, CL; Herron, RM; Hanna, H; Nobiletti, JB; Rios, JA; Reagen, WK; Ley, CA. (2017). Per- and polyfluoroalkyl substances (PFAS) in American Red Cross adult blood donors, 2000-2015. Environ Res 157: 87–95. 10.1016/j.envres.2017.05.013 28528142
Pant, KJ. (2001). Evaluation of a test article in the Salmonella typhimurium/Escherichia coli plate incorporation/preincubation mutation assay in the presence and absence of induced rat liver S-9. (Sponsor’s study no. 132-008). Redfield, AR: Primedica Redfield.
Patel, J; Landers, K; Li, H; Mortimer, RH; Richard, K. (2011). Thyroid hormones and fetal neurological development. J Endocrinol 209: 1–8. 10.1530/JOE-10-0444 21212091
Pop, VJ; Brouwers, EP; Vader, HL; Vulsma, T; van Baar, AL; de Vijlder, JJ. (2003). Maternal hypothyroxinaemia during early pregnancy and subsequent child development: a 3-year follow-up study. Clin Endocrinol 59: 282–288. 10.1046/j.1365-2265.2003.01822.x
Post, GB; Louis, JB; Lippincott, RL; Procopio, NA. (2013). Occurrence of perfluorinated compounds in raw water from New Jersey public drinking water systems. Environ Sci Technol 47: 13266–13275. 10.1021/es402884x 24187954
Puig-Domingo, M; Vila, L. (2013). The implications of iodine and its supplementation during pregnancy in fetal brain development [Review]. Curr Clin Pharmacol 8: 97–109.23062035
Qin, XD; Qian, Z; Vaughn, MG; Huang, J; Ward, P; Zeng, XW; Zhou, Y; Zhu, Y; Yuan, P; Li, M; Bai, Z; Paul, G; Hao, YT; Chen, W; Chen, PC; Dong, GH; Lee, YL. (2016). Positive associations of serum perfluoroalkyl substances with uric acid and hyperuricemia in children from Taiwan. Environ Pollut 212: 519–524. 10.1016/j.envpol.2016.02.050 26970855
Qin, XD; Qian, ZM; Dharmage, SC; Perret, J; Geiger, SD; Rigdon, SE; Howard, S; Zeng, XW; Hu, LW; Yang, BY; Zhou, Y; Li, M; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Chen, W; Lee, YL; Dong, GH. (2017). Association of perfluoroalkyl substances exposure with impaired lung function in children. Environ Res 155: 15–21. 10.1016/j.envres.2017.01.025 28171771
Rabah, SA; Gowan, IL; Pagnin, M; Osman, N; Richardson, SJ. (2019). Thyroid Hormone Distributor Proteins During Development in Vertebrates [Review]. Front Endocrinol (Lausanne) 10: 506. 10.3389/fendo.2019.00506 31440205
Regulatory Science Associates. (2019). A literature review of the current state of the science regarding species differences in the control of, and response to, thyroid hormone perturbations. Part 1: A human health perspective. (RSA/ ECPA005_4111_001). Brussels, Belgium: European Crop Protection Association.
Román, GC; Ghassabian, A; Bongers-Schokking, JJ; Jaddoe, VW; Hofman, A; de Rijke, YB; Verhulst, FC; Tiemeier, H. (2013). Association of gestational maternal hypothyroxinemia and increased autism risk. Ann Neurol 74: 733–742. 10.1002/ana.23976 23943579
Rovet, JF. (2014). The role of thyroid hormones for brain development and cognitive function [Review]. Endocr Dev 26: 26–43. 10.1159/000363153 25231442
Rudmann, DG; Foley, GL. (2018). Chapter 18. Female Reproductive System. In MA Wallig; WM Haschek; CG Rousseaux; B Bolon (Eds.), Fundamentals of toxicologic pathology (3rd ed., pp. 517–545). Cambridge, MA: Academic Press. 10.1016/B978-0-12-809841-7.00018-6
Savin, S; Cvejić, D; Nedić, O; Radosavljević, R. (2003). Thyroid hormone synthesis and storage in the thyroid gland of human neonates. J Pediatr Endocrinol Metab 16: 521–528.12793603
Savu, L; Vranckx, R; Maya, M; Gripois, D; Blouquit, MF; Nunez, EA. (1989). Thyroxine-binding globulin and thyroxine-binding prealbumin in hypothyroid and hyperthyroid developing rats. Biochim Biophys Acta 992: 379–384.2505856
Savu, L; Vranckx, R; Rouaze-Romet, M; Maya, M; Nunez, EA; Tréton, J; Flink, IL. (1991). A senescence up-regulated protein: the rat thyroxine-binding globulin (TBG). Biochim Biophys Acta 1097: 19–22. 10.1016/0925-4439(91)90017-4 1907201
Schaider, LA; Balan, SA; Blum, A; Andrews, DQ; Strynar, MJ; Dickinson, ME; Lunderberg, DM; Lang, JR; Peaslee, GF. (2017). Fluorinated compounds in US fast food packaging. Environ Sci Technol Lett 4: 105–111. 10.1021/acs.estlett.6b00435 30148183
Seo, SH; Son, MH; Choi, SD; Lee, DH; Chang, YS. (2018). Influence of exposure to perfluoroalkyl substances (PFASs) on the Korean general population: 10-year trend and health effects. Environ Int 113: 149–161. 10.1016/j.envint.2018.01.025 29425899
Sepulvado, JG; Blaine, AC; Hundal, LS; Higgins, CP. (2011). Occurrence and fate of perfluorochemicals in soil following the land application of municipal biosolids. Environ Sci Technol 45: 8106–8112. 10.1021/es103903d 21446724
Sferruzzi-Perri, AN; Vaughan, OR; Forhead, AJ; Fowden, AL. (2013). Hormonal and nutritional drivers of intrauterine growth [Review]. Curr Opin Clin Nutr Metab Care 16: 298–309. 10.1097/MCO.0b013e32835e3643 23340010
Shiue, I. (2016). Urinary arsenic, pesticides, heavy metals, phthalates, polyaromatic hydrocarbons, and polyfluoroalkyl compounds are associated with sleep troubles in adults: USA NHANES, 2005-2006. Environ Sci Pollut Res Int 24: 3108–3116. 10.1007/s11356-016-8054-6 27858272
Song, X; Tang, S; Zhu, H; Chen, Z; Zang, Z; Zhang, Y; Niu, X; Wang, X; Yin, H; Zeng, F; He, C. (2018). Biomonitoring PFAAs in blood and semen samples: Investigation of a potential link between PFAAs exposure and semen mobility in China. Environ Int 113: 50–54. 10.1016/j.envint.2018.01.010 29421407
Stagnaro-Green, A; Abalovich, M; Alexander, E; Azizi, F; Mestman, J; Negro, R; Nixon, A; Pearce, EN; Soldin, OP; Sullivan, S; Wiersinga, W. (2011). Guidelines of the American Thyroid Association for the diagnosis and management of thyroid disease during pregnancy and postpartum. Thyroid 21: 1081–1125. 10.1089/thy.2011.0087 21787128
Stenzel, D; Huttner, WB. (2013). Role of maternal thyroid hormones in the developing neocortex and during human evolution. Frontiers in Neuroanatomy 7: 9. 10.3389/fnana.2013.00019 23675325
Sundström, M; Bogdanska, J; Pham, HV; Athanasios, V; Nobel, S; Mcalees, A; Eriksson, J; Depierre, JW; Bergman, Å. (2012). Radiosynthesis of perfluorooctanesulfonate (PFOS) and perfluorobutanesulfonate (PFBS), including solubility, partition and adhesion studies. Chemosphere 87: 865–871. 10.1016/j.chemosphere.2012.01.027 22336737
Thompson, W; Russell, G; Baragwanath, G; Matthews, J; Vaidya, B; Thompson-Coon, J. (2018). Maternal thyroid hormone insufficiency during pregnancy and risk of neurodevelopmental disorders in offspring: A systematic review and meta-analysis. Clin Endocrinol 88: 575–584. 10.1111/cen.13550
Tsai, C; Huang, J; Hwang, BF; Lee, YL. (2010). Household environmental tobacco smoke and risks of asthma, wheeze and bronchitic symptoms among children in Taiwan. Respir Res 11: 11. 10.1186/1465-9921-11-11 20113468
U.S. EPA (U.S. Environmental Protection Agency). (1991a). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1991b). Guidelines for developmental toxicity risk assessment (pp. 1–71). (EPA/600/FR-91/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=23162
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA/600/8-90/066F). Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (1996a). Guidelines for reproductive toxicity risk assessment. Fed Reg 61: 56274–56322.
U.S. EPA (U.S. Environmental Protection Agency). (1996b). Guidelines for reproductive toxicity risk assessment (pp. 1–143). (EPA/630/R-96/009). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-11/documents/guidelines_repro_toxicity.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2006). A framework for assessing health risk of environmental exposures to children (pp. 1–145). (EPA/600/R-05/093F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=158363
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Exposure factors handbook: 2011 edition [EPA Report]. (EPA/600/R-090/052F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=236252
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose (pp. 1–50). (EPA/100/R-11/0001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance. (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance
U.S. EPA (U.S. Environmental Protection Agency). (2014a). Child-specific exposure scenarios examples [EPA Report]. (EPA/600/R-14/217F). Washington, DC. http://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=262211
U.S. EPA (U.S. Environmental Protection Agency). (2014b). Draft: Health effects document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA/822/R-14/002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://peerreview.versar.com/epa/pfoa/pdf/Health-Effects-Document-for-Perfluorooctane-Sulfonate-(PFOS).pdf
U.S. EPA (U.S. Environmental Protection Agency). (2014c). Framework for human health risk assessment to inform decision making. Final [EPA Report]. (EPA/100/R-14/001). Washington, DC: U.S. Environmental Protection, Risk Assessment Forum. https://www.epa.gov/risk/framework-human-health-risk-assessment-inform-decision-making
U.S. EPA (U.S. Environmental Protection Agency). (2014d). Guidance for applying quantitative data to develop data-derived extrapolation factors for interspecies and intraspecies extrapolation [EPA Report]. (EPA/100/R-14/002F). Washington, DC: Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2015-01/documents/ddef-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2014e). Health effects document for perfluorooctanoic acid (PFOA). (EPA/822/R-14/001). Washington, DC: Office of Water, Health and Ecological Criteria Division. https://peerreview.versar.com/epa/pfoa/pdf/Health-Effects-Document-for-Perfluorooctanoic-Acid-(PFOA).pdf
U.S. EPA (U.S. Environmental Protection Agency). (2014f). Provisional peer-reviewed toxicity values for perfluorobutane sulfonate (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) [EPA Report]. (EPA/690/R-14/012F). https://hhpprtv.ornl.gov/issue_papers/PerfluorobutanesulfonicacidPFBS.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2017). Unregulated Contaminant Monitoring Rule 3 (2013-2015) occurrence data. Retrieved from https://www.epa.gov/dwucmr/occurrence-data-unregulated-contaminant-monitoring-rule
U.S. EPA (U.S. Environmental Protection Agency). (2018). Safe drinking water information system [Database]. Retrieved from https://www3.epa.gov/enviro/facts/sdwis/search.html
U.S. EPA (U.S. Environmental Protection Agency). (2019). EPA’s per- and polyfluoroalkyl substances (PFAS) action plan. (EPA 823R18004). https://www.epa.gov/sites/production/files/2019-02/documents/pfas_action_plan_021319_508compliant_1.pdf
van den Hove, MF; Beckers, C; Devlieger, H; de Zegher, F; De Nayer, P. (1999). Hormone synthesis and storage in the thyroid of human preterm and term newborns: effect of thyroxine treatment [Review]. Biochimie 81: 563–570.10403191
Vulsma, T; Gons, MH; de Vijlder, JJ. (1989). Maternal-fetal transfer of thyroxine in congenital hypothyroidism due to a total organification defect or thyroid agenesis. N Engl J Med 321: 13–16. 10.1056/NEJM198907063210103 2733742
Wang, B; Zhang, R; Jin, F; Lou, H; Mao, Y; Zhu, W; Zhou, W; Zhang, P; Zhang, J. (2017). Perfluoroalkyl substances and endometriosis-related infertility in Chinese women. Environ Int 102: 207–212. 10.1016/j.envint.2017.03.003 28283302
Wang, Y; Rogan, WJ; Chen, PC; Lien, GW; Chen, HY; Tseng, YC; Longnecker, MP; Wang, SL. (2014). Association between maternal serum perfluoroalkyl substances during pregnancy and maternal and cord thyroid hormones: Taiwan maternal and infant cohort study. Environ Health Perspect 122: 529–534. 10.1289/ehp.1306925 24577800
Wang, Z; Cousins, IT; Scheringer, M; Hungerbühler, K. (2013). Fluorinated alternatives to long-chain perfluoroalkyl carboxylic acids (PFCAs), perfluoroalkane sulfonic acids (PFSAs) and their potential precursors [Review]. Environ Int 60: 242–248. 10.1016/j.envint.2013.08.021 24660230
Wasco, EC; Martinez, E; Grant, KS; St Germain, EA; St Germain, DL. (2003). Determinants of iodothyronine deiodinase activities in rodent uterus. Endocrinology 144: 4253–4261. 10.1210/en.2003-0490 12959985
Weaver, YM; Ehresman, DJ; Butenhoff, JL; Hagenbuch, B. (2010). Roles of rat renal organic anion transporters in transporting perfluorinated carboxylates with different chain lengths. Toxicol Sci 113: 305–314. 10.1093/toxsci/kfp275 19915082
White, SS; Calafat, AM; Kuklenyik, Z; Villanueva, L; Zehr, RD; Helfant, L; Strynar, MJ; Lindstrom, AB; Thibodeaux, JR; Wood, C; Fenton, SE. (2007). Gestational PFOA exposure of mice is associated with altered mammary gland development in dams and female offspring. Toxicol Sci 96: 133–144. 10.1093/toxsci/kfl177 17132714
Woldemeskel, M. (2017). Chapter 64 –Toxicologic pathology of the reproductive system. In RC Gupta (Ed.), Reproductive and Developmental Toxicology (Second Edition) (2nd ed., pp. 745–763). San Diego, CA: Academic Press. 10.1016/B978-0-12-804239-7.00064-0
Wong, F; MacLeod, M; Mueller, JF; Cousins, IT. (2014). Enhanced elimination of perfluorooctane sulfonic acid by menstruating women: evidence from population-based pharmacokinetic modeling. Environ Sci Technol 48: 8807–8814. 10.1021/es500796y 24943117
Xu, J. (2001). Test for chemical induction of chromosome aberration in cultured Chinese hamster ovary (CHO) cells with and without metabolic activation. (Sponsor’s study no. 132-009). Redfield, AR: Primedica Redfield.
Xu, Y; Fletcher, T; Pineda, D; Lindh, CH; Nilsson, C; Glynn, A; Vogs, C; Norström, K; Lilja, K; Jakobsson, K; Li, Y. (2020). Serum Half-Lives for Short- and Long-Chain Perfluoroalkyl Acids after Ceasing Exposure from Drinking Water Contaminated by Firefighting Foam. Environ Health Perspect 128: 77004. 10.1289/EHP6785 32648786
Yang, L; Li, J; Lai, J; Luan, H; Cai, Z; Wang, Y; Zhao, Y; Wu, Y. (2016). Placental transfer of perfluoroalkyl substances and associations with thyroid hormones: Beijing prenatal exposure study. Sci Rep 6: 21699. 10.1038/srep21699 26898235
Yao, Q; Shi, R; Wang, C; Han, W; Gao, Y; Zhang, Y; Zhou, Y; Ding, G; Tian, Y. (2019). Cord blood per- and polyfluoroalkyl substances, placental steroidogenic enzyme, and cord blood reproductive hormone. Environ Int 129: 573–582. 10.1016/j.envint.2019.03.047 31174145
York, RG. (2002). Oral (gavage) developmental toxicity study of potassium perfluorobutane sulfonate (PFBS) in rats. (Argus Research Protocol Number 418-023). St. Paul, MN: 3M Corporate Toxicology.
York, RG. (2003a). Oral (galvage) dosage-range developmental toxicity study of potassium perfluorobutane sulfonate (PFBS) in rats. (Sponsor’s study no. T-7485.11). Horsham, PA: Argus Research.
York, RG. (2003b). Oral (gavage) repeated dose 90-day toxicity study of potassium perfluorobutane sulfonate (PFBS) in rats. (Argus Research Protocol Number 418-026). Washington, D.C.: U.S. Environmental Protection Agency.
York, RG. (2003c). Oral (gavage) two-generation (one litter per generation) reproduction study of perfluorobutane sulfonate (PFBS) in rats. (Argus Research Protocol Number 418-021). Washington, D.C.: U.S. Environmental Protection Agency.
York, RG. (2003d). Oral (gavage) two-generation (one litter per generation) reproduction study of perfluorobutane sulfonate (PFBS) in rats. Appendix D. Report tables - F1 generation male rats. (Argus Research Protocol Number 418-021). Washington, D.C.: U.S. Environmental Protection Agency.
York, RG. (2003e). Oral (gavage) two-generation (one litter per generation) reproduction study of perfluorobutane sulfonate (PFBS) in rats. Appendix K. Hisopathology report. (Argus Research Protocol Number 418-021). Washington, D.C.: U.S. Environmental Protection Agency.
Zeng, XW; Qian, Z; Emo, B; Vaughn, M; Bao, J; Qin, XD; Zhu, Y; Li, J; Lee, YL; Dong, GH. (2015). Association of polyfluoroalkyl chemical exposure with serum lipids in children. Sci Total Environ 512–513: 364–370. 10.1016/j.scitotenv.2015.01.042
Zhang, S; Tan, R; Pan, R; Xiong, J; Tian, Y; Wu, J; Chen, L. (2018). Association of perfluoroalkyl and polyfluoroalkyl substances with premature ovarian insufficiency in Chinese women. J Clin Endocrinol Metab 103: 2543–2551. 10.1210/jc.2017-02783 29986037
Zhang, X; Lohmann, R; Dassuncao, C; Hu, XC; Weber, AK; Vecitis, CD; Sunderland, EM. (2016). Source attribution of poly- and perfluoroalkyl substances (PFASs) in surface waters from Rhode Island and the New York metropolitan area. Environ Sci Technol Lett 3: 316–321. 10.1021/acs.estlett.6b00255 28217711
Zhang, Y; Beesoon, S; Zhu, L; Martin, JW. (2013). Biomonitoring of perfluoroalkyl acids in human urine and estimates of biological half-life. Environ Sci Technol 47: 10619–10627. 10.1021/es401905e 23980546
Zhao, Z; Xie, Z; Moeller, A; Sturm, R; Tang, J; Zhang, G; Ebinghaus, R. (2012). Distribution and long-range transport of polyfluoroalkyl substances in the Arctic, Atlantic Ocean and Antarctic coast. Environ Pollut 170: 71–77. 10.1016/j.envpol.2012.06.004 22771353
Zhou, W; Zhang, L; Tong, C; Fang, F; Zhao, S; Tian, Y; Tao, Y; Zhang, J. (2017a). Plasma perfluoroalkyl and polyfluoroalkyl substances concentration and menstrual cycle characteristics in preconception women. Environ Health Perspect 125: 067012. 10.1289/EHP1203 28657892
Zhou, Y; Bao, WW; Qian, ZM; Dee Geiger, S; Parrish, KL; Yang, BY; Lee, YL; Dong, GH. (2017b). Perfluoroalkyl substance exposure and urine CC16 levels among asthmatics: A case-control study of children. Environ Res 159: 158–163. 10.1016/j.envres.2017.08.005 28802206
Zhou, Y; Hu, LW; Qian, ZM; Chang, JJ; King, C; Paul, G; Lin, S; Chen, PC; Lee, YL; Dong, GH. (2016). Association of perfluoroalkyl substances exposure with reproductive hormone levels in adolescents: By sex status. Environ Int 94: 189–195. 10.1016/j.envint.2016.05.018 27258660
Zhu, Y; Qin, XD; Zeng, XW; Paul, G; Morawska, L; Su, MW; Tsai, CH; Wang, SQ; Lee, YL; Dong, GH. (2016). Associations of serum perfluoroalkyl acid levels with T-helper cell-specific cytokines in children: By gender and asthma status. Sci Total Environ 559: 166–173. 10.1016/j.scitotenv.2016.03.187 27060656
Zoeller, RT; Tan, SW; Tyl, RW. (2007). General background on the hypothalamic-pituitary-thyroid (HPT) axis [Review]. Crit Rev Toxicol 37: 11–53. 10.1080/10408440601123446 17364704