# APPENDIX G QUALITY ASSURANCE

U.S. EPA has an agency-wide quality assurance (QA) policy, and that policy is outlined in the EPA Quality Manual for Environmental Programs (see CIO 2105-P-01-0 (https://www.epa.gov/irmpoli8/epa-quality-manual-environmental-program-requirements-implementing-quality-system)) and follows the specifications outlined in U.S. EPA Order CIO 2105.0 (https://www.epa.gov/irmpoli8/environmental-information-quality-policy). The goal of the QA policy is to assure that environmental data used to support Agency decisions are of adequate quality and usability for their intended purpose.

As required by CIO 2105.0 (https://www.epa.gov/irmpoli8/environmental-information-quality-policy), ORD maintains a Quality Management Program, which is documented in an internal Quality Management Plan (QMP). The latest version was developed in 2013 using the Guidance for Developing Quality Systems for Environmental Programs (QA/G-1). An NCEA-specific QMP was also developed in 2013 as an appendix to the ORD QMP. Quality assurance for products developed within CPHEA is managed under the ORD QMP and applicable appendices.

This assessment has been designated as High Profile and is classified as QA Category A. Category A designations require reporting of all critical QA activities, including audits.

Another requirement of the Agency quality system includes the use of project-specific planning documents referred to as Quality Assurance Project Plans (QAPPs) that describe how specific data collection efforts will be planned, implemented, and assessed. Specific management of quality assurance in this assessment is documented in an Umbrella Quality Assurance Project Plan, which was developed using the U.S. EPA Guidance for Quality Assurance Project Plans (QA/G-5) (https://www.epa.gov/quality/guidance-quality-assurance-project-plans-epa-qag-5). The latest approved version of the QAPP is dated September 2019. During assessment development, additional QAPPs may be applied for quality assurance management. They include:

Title | Document Number | Date
Program Quality Assurance Project Plan (PQAPP) for the Provisional Peer-Reviewed Toxicity Values (PPRTVs) and Related Assessments/Documents | L-CPAD-0032718-QP | October 2015 (last updated 2020)
Umbrella Quality Assurance Project Plan for NCEA PFAS Toxicity Assessments | B-IO-0031652-QP-1-2 | July 2018 (last updated September 2019)
Quality Assurance Project Plan (QAPP) for Enhancements to Benchmark Dose Software (BMDS) | B-003742-QP-1-0 | July 2019

During assessment development, this project underwent quality audit:

Date | Type of Audit | Major Findings | Actions Taken
September 18, 2020 | Technical System Audit | None | None

During assessment development, the assessment was subjected to external reviews by individual letters from expert peer reviewers and by other federal agency partners including the Executive Offices of the President. Peer-review reports during these review steps are available at https://www.epa.gov/pfas/learn-about-human-health-toxicity-assessment-pfbs. In addition, the assessment underwent public comment from November 21, 2018 to January 22, 2019. The public comments are available in the Docket ID No. EPA-HQ-OW-2018-0614. Prior to release, the final draft assessment was submitted to management and QA clearance. During this step the CPHEA QA director and QA managers review the project QA documentation and ensure U.S. EPA QA requirements have been met.