# APPENDIX F BENCHMARK DOSE MODELING RESULTS

## F.1 MODELING OF NONCANCER ENDPOINTS

As discussed in the body of the report under “Derivation of Oral Reference Doses,” the endpoints selected for benchmark dose (BMD) modeling were incidence of renal papillary epithelial tubular/ductal hyperplasia in rats from Lieder et al. (2009a) and Lieder et al. (2009b); thyroid hormones in pregnant mice and offspring at Postnatal Days (PNDs) 1, 30, and 60 from Feng et al. (2017) and adult rats from NTP (2019); and developmental effects (i.e., eye opening, first estrus, vaginal opening) from Feng et al. (2017). The animal doses in the study, converted to human equivalent doses (HEDs), were used in the BMD modeling; the data are available for download in Health Assessment Workspace Collaborative (HAWC). BMD modeling was conducted by experts in quantitative Benchmark Dose Software (BMDS) analysis and interpretation. Links to the data and modeling output are included in Table F-1. The selected point of departure (POD) (HED) listed in Table F-1 represents the best-fitting model for each endpoint; if the data were determined not to be amenable to BMD modeling, the no-observed-adverse-effect level (NOAEL) or lowest-observed-adverse-effect level (LOAEL) is listed. Figure F-1 illustrates the doses examined and NOAEL, LOAEL, BMD, and benchmark dose lower confidence limit (BMDL) values for the potential critical effects.

Table F-1 Candidate PODs for the Derivation of the Subchronic and Chronic RfDs for PFBS (CASRN 375-73-5) and the Related Compound K^+^PFBS (CASRN 29420-49-3)

Endpoint/Reference | Species/Life Stage—Sex | Selected POD (HED)^a^ (mg/kg-d)
Kidney effects
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009a) | Rat—male | BMDL_10_ = 0.489 (https://hawcprd.epa.gov/bmd/session/100000008/)
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009a) | Rat—female | BMDL_10_ = 0.300 (https://hawcprd.epa.gov/bmd/session/100000010/)
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/P_0_—male | BMDL_10_ = 0.351 (https://hawcprd.epa.gov/bmd/session/100000040/)
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/P_0_—female | BMDL_10_ = 0.265 (https://hawcprd.epa.gov/bmd/session/100000048/)
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/F_1_—male | BMDL_10_ = 0.776 (https://hawcprd.epa.gov/bmd/session/100000042/)
Kidney histopathology—papillary epithelial tubular/ductal hyperplasia—Lieder et al. (2009b) | Rat/F_1_—female | BMDL_10_ = 0.478 (https://hawcprd.epa.gov/bmd/session/100000043/)
Thyroid effects
Total T_4_—NTP (2019) | Rat—male | LOAEL = 0.34 (https://hawcprd.epa.gov/bmd/session/100000056/)
Total T_4_—NTP (2019) | Rat—female | BMDL_1SD_ = 0.037 (https://hawcprd.epa.gov/bmd/session/100000050/)
Free T_4_—NTP (2019) | Rat—male | LOAEL = 0.34 (https://hawcprd.epa.gov/bmd/session/100000055/)
Free T_4_—NTP (2019) | Rat—female | BMDL_1SD_ = 0.027 (https://hawcprd.epa.gov/bmd/session/100000052/)
Total T_4_—Feng et al. (2017) | Mouse/P_0_—female | BMDL_1SD_ = 0.093 (https://hawcprd.epa.gov/bmd/session/100000078/)
Free T_4_—Feng et al. (2017) | Mouse/P_0_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000019/)
TSH—Feng et al. (2017) | Mouse/P_0_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000022/)
Total T_4_ PND 1 (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000057/)
Total T_4_ PND 1 (litter n)^b^ — Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.095 (https://hawcprd.epa.gov/bmd/session/100000027/) (BMDL_1SD_ = 0.25)
Total T_4_ PND 30—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000036/)
Total T_4_ PND 60—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000037/)
TSH PND 30—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000038/)
Developmental effects
Eyes opening (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000083/)
Eyes opening (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.073 (https://hawcprd.epa.gov/bmd/session/100000024/) (BMDL_1SD_ = 0.16)
Vaginal opening (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.15 (https://hawcprd.epa.gov/bmd/session/100000026/) (BMDL_1SD_ = 0.35)
Vaginal opening (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | BMDL_0.5SD_ = 0.094 (https://hawcprd.epa.gov/bmd/session/100000026/) (BMDL_1SD_ = 0.22)
First estrous (fetal n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000084/)
First estrous (litter n)^b^—Feng et al. (2017) | Mouse/F_1_—female | NOAEL = 0.21 (https://hawcprd.epa.gov/bmd/session/100000025/)

a Following U.S. EPA (2011b) guidance, animal doses from candidate principal studies were converted to HEDs through the application of a DAF, where HED = dose × DAF. See Table 8 in the assessment for full details. Links are to the HAWC BMDS session containing full modeling results for that endpoint.

b Fetal endpoints from Feng et al. (2017) were modeled alternatively using dose group sizes based either on total number of fetuses or dams. Given that it appears that Feng et al. (2017) did not use the litter as the statistical unit of analysis, it is unclear if the study-reported standard errors pertain to litters or fetuses. Alternatively, modeling fetal endpoints using litter n or fetal n provides two modeling results that bracket the “true” variance among all fetuses in a dose group (i.e., using the fetal n will underestimate the true variance while using the litter n will overestimate the true variance). Individual animal data were requested from study authors but were unable to be obtained.

BMDL = benchmark dose lower confidence limit; BMDS = benchmark dose software; DAF = dosimetric adjustment factor; HAWC = Health Assessment Workspace Collaborative; HED = human equivalent dose; K^+^PFBS = potassium perfluorobutane sulfonate; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PFBS = perfluorobutane sulfonic acid; PND = postnatal day; POD = point of departure; RfD = oral reference dose; SD = standard deviation; T_4_ = total thyroxine; TSH = thyroid-stimulating hormone.

Figure F-1 Candidate PODs for the Derivation of the Subchronic and Chronic RfDs for PFBS

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-candidate-pods-subchronic-and-chronic-rfd/))

Plot of candidate points of departure for the derivation of the subchronic and chronic RfDs, including benchmark dose (BMD), benchmark dose lower confidence limit (BMDL), no observed adverse effect level (NOAEL), and lowest observed adverse effect level. Endpoints and studies shown are papillary tubular/ductal epithelium hyperplasia from Lieder 2009a and Lieder 2009b, Total and free T4 from NTP 2018 and Feng 2017, TSH from Feng 2017, and developmental effects (eye opening, first estrous, and vaginal opening) from Feng 2017. Candidate PODs are presented on an axis of doses spanning 0.01 mg/kg-day to 10 mg/kg-day.

## F.2 MODELING PROCEDURE FOR CONTINUOUS NONCANCER DATA

BMD modeling of continuous data was conducted on the HAWC website using the U.S. Environmental Protection Agency’s (U.S. EPA’s) BMDS (Version 2.7). All continuous models available within the software were fit using a benchmark response (BMR) of 1 standard deviation (SD). For continuous data of effects in developing offspring, including thyroid hormone changes, a BMR of 0.5 SD change from the control mean is used to account for effects occurring in a sensitive life stage. A 1 SD BMR is also presented as the basis for model comparison as directed in the U.S. EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012). An adequate fit is judged based on the χ^2^ goodness-of-fit p-value (p > 0.1), magnitude of the scaled residuals in the vicinity of the BMR, and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination is made as to whether the variance across dose groups is homogeneous. If a homogeneous variance model is deemed appropriate based on the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. If the test for homogeneity of variance is rejected (p < 0.1), the model is run again while modeling the variance as a power function of the mean to account for this nonhomogeneous variance. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.1), the data set is considered unsuitable for BMD modeling. In cases in which a model with # parameters = # dose-groups was fit to the data set, all parameters were estimated, and no p-value was calculated, that model was not considered for estimating a POD unless no other model provided adequate fit. Among all models providing adequate fit, the BMDL from the model with the lowest Akaike’s information criterion (AIC) was selected as a potential POD when BMDL values were sufficiently close (within threefold). Otherwise, the lowest BMDL was selected as a potential POD from which to derive the oral reference dose/inhalation reference concentration (RfD/RfC).

### F.2.1 Modeling Predictions for Serum Total T_4_ in PND 1 Female Offspring (litter n)

The modeling results for total T_4_ in PND 1 female offspring (litter n) exposed Gestation Days (GDs) 1–20 are shown in Table F-2. The Exponential 4 model (see Figure F-2) was selected given appropriate fit to the data and that the BMDL values differed by greater than threefold. The output for the U.S. EPA’s BMDS model run is also provided below.

Table F-2 Modeling Results for Total T_4_ in PND 1 Female Offspring (Litter n) Exposed GDs 1–20^a^

Model | Global p-Value | AIC | BMD_0.5SD_ (HED) (mg/kg-d) | BMDL_0.5SD_ (HED) (mg/kg-d) | BMD_1SD_ (HED) (mg/kg-d) | BMDL_1SD_ (HED) (mg/kg-d) | Residual of Interest
Linear | 0.5652 | −4.74898 | 0.7778 | 0.5120 | 1.5557 | 1.0241 | 0.348
Polynomial | 0.5652 | −4.74898 | 0.7778 | 0.5120 | 1.5557 | 1.0241 | 0.348
Power | 0.5652 | −4.74898 | 0.7778 | 0.5120 | 1.5557 | 1.0241 | 0.348
Hill | −999 | −1.89 | 0.368 | 0.0704 | 0.8677 | 0.2294 | −6.01 × 10^−7^
Exponential-M2 | 0.77 | −5.3672 | 0.5546 | 0.3017 | 1.2555 | 0.6694 | −0.5752
Exponential-M3 | 0.77 | −5.3672 | 0.5546 | 0.3017 | 1.2555 | 0.6694 | −0.5752
Exponential-M4 ^b^ | 0.8583 | −3.8581 | 0.3346 | 0.0951 | 0.8708 | 0.2498 | −0.08305
Exponential-M5 | −999 | −1.89 | 0.3807 | 0.0958 | 0.8669 | 0.2517 | −4.356 × 10^−7^

a Feng et al. (2017).

b Selected model. Exponential 4 model was selected given appropriate fit to the data and that the BMDL values differed by greater than threefold. The Hill and Exponential 5 models were not selected because they did not return a p-value.

AIC = Akaike’s information criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.5 SD = exposure concentration associated with 0.5 SD change from the control mean); BMR = benchmark response; GD = gestation day; HED = human equivalent dose; PND = postnatal day; SD = standard deviation; T_4_ = thyroxine.

Figure F-2 Exponential (Model 4) for Total T_4_ in PND 1 Female Offspring (Litter n) Exposed GDs 1–20 (Feng et al., 2017)

Figure F-2 is the Benchmark Dose Modeling curve fit output for the Exponential (model 4) estimate for total T4 in postnatal day 1 female offspring using the litter n from the Feng et al. 2017 study. The dose-response plot has dose on the x-axis ranging from 0 to 2.5 mg/kg-day human equivalent doses and total T4 response on the y-axis in microgram/mL. The graph shows a decreasing curve with NOAEL (0.21) and LOAEL (0.86) marked.

====================================================================  
      Exponential Model.  (Version: 1.11;  Date: 03/14/2017)  
      Input Data File: C:\Windows\TEMP\bmds-dfile-k4vsthrz.(d)   
      Gnuplot Plotting File:   
      Mon Aug 17 15:16:06 2020 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the response function by Model:  
      Model 2:     Y[dose] = a * exp{sign * b * dose} 
      Model 3:     Y[dose] = a * exp{sign * (b * dose)^d} 
      Model 4:     Y[dose] = a * [c-(c-1) * exp{-b * dose}] 
      Model 5:     Y[dose] = a * [c-(c-1) * exp{-(b * dose)^d}] 
 
    Note: Y[dose] is the median response for exposure = dose; 
          sign = +1 for increasing trend in data; 
          sign = -1 for decreasing trend. 
 
      Model 2 is nested within Models 3 and 4. 
      Model 3 is nested within Model 5. 
      Model 4 is nested within Model 5. 
 
 
   Dependent variable = Response 
   Independent variable = Dose 
   Data are assumed to be distributed: normally 
   Variance Model: exp(lnalpha +rho *ln(Y[dose])) 
   rho is set to 0. 
   A constant variance model is fit. 
 
   Total number of dose groups = 4 
   Total number of records with missing values = 0 
   Maximum number of iterations = 500 
   Relative Function Convergence has been set to: 1e-008 
   Parameter Convergence has been set to: 1e-008 
 
   MLE solution provided: Exact 
 
 
                  Initial Parameter Values 
 
                  Variable          Model 4 
                  --------          -------- 
                    lnalpha          -1.29725           
                        rho                 0 Specified 
                          a             1.512           
                          b           1.50054           
                          c          0.434618           
                          d                 1 Specified 
 
 
 
                     Parameter Estimates 
 
                   Variable          Model 4          Std.  Err. 
                   --------          -------          --------- 
                    lnalpha            -1.29645           0.0611565 
                          a             1.45283            0.148029 
                          b             1.10398             1.13864 
                          c            0.417162            0.225239 
 
     NC = No Convergence 
 
 
            Table of Stats From Input Data 
 
     Dose      N         Obs Mean     Obs Std Dev 
     -----    ---       ----------   ------------- 
         0     10         1.44        0.329 
      0.21     10          1.3        0.657 
      0.86     10         0.92        0.493 
      2.14     10         0.69        0.657 
 
 
                  Estimated Values of Interest 
 
      Dose      Est Mean      Est Std     Scaled Residual 
    ------    ----------    ---------    ---------------- 
         0         1.453        0.523         -0.07759 
      0.21         1.278        0.523           0.1354 
      0.86        0.9337        0.523         -0.08305 
      2.14        0.6858        0.523          0.02529 
 
 
 
   Other models for which likelihoods are calculated: 
 
     Model A1:        Yij = Mu(i) + e(ij) 
               Var{e(ij)} = Sigma^2 
 
     Model A2:        Yij = Mu(i) + e(ij) 
               Var{e(ij)} = Sigma(i)^2 
 
     Model A3:        Yij = Mu(i) + e(ij) 
               Var{e(ij)} = exp(lalpha + log(mean(i)) * rho) 
 
     Model  R:        Yij = Mu + e(i) 
               Var{e(ij)} = Sigma^2 
 
 
                                Likelihoods of Interest 
 
                     Model      Log(likelihood)      DF         AIC 
                    -------    -----------------    ----   ------------ 
                        A1        5.944999            5     -1.889998 
                        A2        8.698072            8     -1.396144 
                        A3        5.944999            5     -1.889998 
                         R       0.3138778            2      3.372244 
                         4        5.929054            4     -3.858109 
 
 
   Additive constant for all log-likelihoods =     -36.76.   This constant added to the 
   above values gives the log-likelihood including the term that does not 
   depend on the model parameters. 
 
 
                                 Explanation of Tests 
 
   Test 1:  Does response and/or variances differ among Dose levels? (A2 vs. R) 
   Test 2:  Are Variances Homogeneous? (A2 vs. A1) 
   Test 3:  Are variances adequately modeled? (A2 vs. A3) 
 
   Test 6a: Does Model 4 fit the data? (A3 vs 4) 
 
 
                            Tests of Interest 
 
     Test          -2*log(Likelihood Ratio)       D.  F.          p-value 
   --------        ------------------------      ------     -------------- 
     Test 1                         16.77           6             0.01017 
     Test 2                         5.506           3              0.1383 
     Test 3                         5.506           3              0.1383 
    Test 6a                       0.03189           1              0.8583 
 
 
     The p-value for Test 1 is less than .05.   There appears to be a 
     difference between response and/or variances among the dose 
     levels, it seems appropriate to model the data. 
 
     The p-value for Test 2 is greater than .1.   A homogeneous 
     variance model appears to be appropriate here. 
 
     The p-value for Test 3 is greater than .1.   The modeled 
     variance appears to be appropriate here. 
 
     The p-value for Test 6a is greater than .1.   Model 4 seems 
     to adequately describe the data. 
 
 
   Benchmark Dose Computations: 
 
     Specified Effect = 1.000000 
 
            Risk Type = Estimated standard deviations from control 
 
     Confidence Level = 0.950000 
 
                  BMD =      0.87078 
 
                 BMDL =     0.249811 
 
                 BMDU =        21400 
 
 
 ====================================================================  
      Exponential Model.  (Version: 1.11;  Date: 03/14/2017)  
      Input Data File: C:\Windows\TEMP\bmds-dfile-17lffb4f.(d)   
      Gnuplot Plotting File:   
                                                          Mon Aug 17 15:16:07 2020 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the response function by Model:  
      Model 2:     Y[dose] = a * exp{sign * b * dose} 
      Model 3:     Y[dose] = a * exp{sign * (b * dose)^d} 
      Model 4:     Y[dose] = a * [c-(c-1) * exp{-b * dose}] 
      Model 5:     Y[dose] = a * [c-(c-1) * exp{-(b * dose)^d}] 
 
    Note: Y[dose] is the median response for exposure = dose; 
          sign = +1 for increasing trend in data; 
          sign = -1 for decreasing trend. 
 
      Model 2 is nested within Models 3 and 4. 
      Model 3 is nested within Model 5. 
      Model 4 is nested within Model 5. 
 
 
   Dependent variable = Response 
   Independent variable = Dose 
   Data are assumed to be distributed: normally 
   Variance Model: exp(lnalpha +rho *ln(Y[dose])) 
   rho is set to 0. 
   A constant variance model is fit. 
 
   Total number of dose groups = 4 
   Total number of records with missing values = 0 
   Maximum number of iterations = 500 
   Relative Function Convergence has been set to: 1e-008 
   Parameter Convergence has been set to: 1e-008 
 
   MLE solution provided: Exact 
 
 
                  Initial Parameter Values 
 
                  Variable          Model 4 
                  --------          -------- 
                    lnalpha          -1.29725           
                        rho                 0 Specified 
                          a             1.512           
                          b           1.50054           
                          c          0.434618           
                          d                 1 Specified 
 
 
 
                     Parameter Estimates 
 
                   Variable          Model 4          Std.  Err. 
                   --------          -------          --------- 
                    lnalpha            -1.29645           0.0611565 
                          a             1.45283            0.148029 
                          b             1.10398             1.13864 
                          c            0.417162            0.225239 
 
     NC = No Convergence 
 
 
            Table of Stats From Input Data 
 
     Dose      N         Obs Mean     Obs Std Dev 
     -----    ---       ----------   ------------- 
         0     10         1.44        0.329 
      0.21     10          1.3        0.657 
      0.86     10         0.92        0.493 
      2.14     10         0.69        0.657 
 
 
                  Estimated Values of Interest 
 
      Dose      Est Mean      Est Std     Scaled Residual 
    ------    ----------    ---------    ---------------- 
         0         1.453        0.523         -0.07759 
      0.21         1.278        0.523           0.1354 
      0.86        0.9337        0.523         -0.08305 
      2.14        0.6858        0.523          0.02529 
 
 
 
   Other models for which likelihoods are calculated: 
 
     Model A1:        Yij = Mu(i) + e(ij) 
               Var{e(ij)} = Sigma^2 
 
     Model A2:        Yij = Mu(i) + e(ij) 
               Var{e(ij)} = Sigma(i)^2 
 
     Model A3:        Yij = Mu(i) + e(ij) 
               Var{e(ij)} = exp(lalpha + log(mean(i)) * rho) 
 
     Model  R:        Yij = Mu + e(i) 
               Var{e(ij)} = Sigma^2 
 
 
                                Likelihoods of Interest 
 
                     Model      Log(likelihood)      DF         AIC 
                    -------    -----------------    ----   ------------ 
                        A1        5.944999            5     -1.889998 
                        A2        8.698072            8     -1.396144 
                        A3        5.944999            5     -1.889998 
                         R       0.3138778            2      3.372244 
                         4        5.929054            4     -3.858109 
 
 
   Additive constant for all log-likelihoods =     -36.76.   This constant added to the 
   above values gives the log-likelihood including the term that does not 
   depend on the model parameters. 
 
 
                                 Explanation of Tests 
 
   Test 1:  Does response and/or variances differ among Dose levels? (A2 vs. R) 
   Test 2:  Are Variances Homogeneous? (A2 vs. A1) 
   Test 3:  Are variances adequately modeled? (A2 vs. A3) 
 
   Test 6a: Does Model 4 fit the data? (A3 vs 4) 
 
 
                            Tests of Interest 
 
     Test          -2*log(Likelihood Ratio)       D.  F.          p-value 
   --------        ------------------------      ------     -------------- 
     Test 1                         16.77           6             0.01017 
     Test 2                         5.506           3              0.1383 
     Test 3                         5.506           3              0.1383 
    Test 6a                       0.03189           1              0.8583 
 
 
     The p-value for Test 1 is less than .05.   There appears to be a 
     difference between response and/or variances among the dose 
     levels, it seems appropriate to model the data. 
 
     The p-value for Test 2 is greater than .1.   A homogeneous 
     variance model appears to be appropriate here. 
 
     The p-value for Test 3 is greater than .1.   The modeled 
     variance appears to be appropriate here. 
 
     The p-value for Test 6a is greater than .1.   Model 4 seems 
     to adequately describe the data. 
 
 
   Benchmark Dose Computations: 
 
     Specified Effect = 0.500000 
 
            Risk Type = Estimated standard deviations from control 
 
     Confidence Level = 0.950000 
 
                  BMD =      0.33455 
 
                 BMDL =    0.0950923 
 
                 BMDU =      1.22544

### F.3 MODELING PROCEDURE FOR DICHOTOMOUS NONCANCER DATA

BMD modeling of dichotomous noncancer data (see Figure F-1) was conducted on the HAWC website using the U.S. EPA’s BMDS Version 2.7. For these data, the Gamma, Logistic, Log-Logistic, Log-Probit, Multistage, Probit, and Weibull dichotomous models available within the software were fit using a BMR of 10% extra risk. The Multistage model is run for all polynomial degrees up to n − 2, where n is the number of dose groups including control. Adequacy of model fit was judged based on the χ^2^ goodness-of-fit p-value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined BMR (absolute value < 2.0), and visual inspection of the model fit. In the cases where no best model was found to fit to the data, use of a reduced data set without the high-dose group was further attempted for modeling and the result was presented along with that of the full data set. In cases in which a model with # parameters = # dose-groups was fit to the data set, all parameters were estimated, and no p-value was calculated, that model was not considered for estimating a POD unless no other model provided adequate fit. Among all models providing adequate fit, the BMDL from the model with the lowest AIC was selected as a potential POD when BMDL values were sufficiently close (within threefold) (see Table F-1). Otherwise, the lowest BMDL was selected as a potential POD.