# APPENDIX E ADDITIONAL DATA FIGURES

Figure E-1 Serum Free and Total Thyroxine (T_4_) Response in Animals Following K^+^PFBS Exposure

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t4-effect-size-animal/))

Forest plot of data evaluating serum free and total thyroxine (T4) responses to K+PFBS in animals. The figure shows percent change from the control response and 95% confidence interval at all exposure doses from NTP 2018 and Feng et al. 2017. Dose-dependent decreases in free and total T4 were observed in male and female rats and mice. Statistically significant decreases were observed in the majority of dose groups.

Figure E-2 Serum Total Triiodothyronine (T_3_) Response in Animals Following K^+^PFBS Exposure

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-t3-effect-size-animal/))

Forest plot of data evaluating serum total triiodothyronine (T3) responses to K+PFBS in animals. The figure shows percent change from the control response and 95% confidence interval at all exposure doses from NTP 2018 and Feng et al. 2017. Dose-dependent decreases in total T3 were observed in male and female rats and mice. Statistically significant decreases were observed in the majority of dose groups.

Figure E-3 Serum Thyroid-Stimulating Hormone (TSH) Response in Animals Following K^+^PFBS Exposure

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-tsh-effect-size-animal/))

Forest plot of data evaluating serum thyroid-stimulating hormone (TSH) responses to K+PFBS in animals. The figure shows percent change from the control response and 95% confidence interval at all exposure doses from NTP 2018 and Feng et al. 2017. Most exposure doses show no statistically significant change from control. Small increases of between 10-25% change are shown at 200 and 500 mg/kg-day in P0 and PND30 mice.

Figure E-4 Developmental Effects (Eye Opening) Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-eye-opening-effect-size-animal/))

Forest plot of data evaluating eye opening following exposure to K+PFBS in animals. The figure shows percent change from the control response and 95% confidence interval at all exposure doses from Feng et al. 2017. A statistically significant increase is shown at 200 and 500 mg/kg-day from Feng 2017. Results are presented using litter n or fetal n to calculate variability from the Feng et al study. Using litter n results in larger 95% confidence intervals around the mean.

Figure E-5 Developmental Effects (First Estrus) Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-estrous-cyclicity-effect-size-animal/))

Forest plot of data evaluating first estrus following exposure to K+PFBS in animals. The figure shows percent change from the control response and 95% confidence interval at all exposure doses from Feng et al. 2017. A statistically significant increase is shown at 200 and 500 mg/kg-day for estrous cycle diestrus.

Figure E-6 Developmental Effects (Vaginal Patency) Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-vaginal-opening-effect-size-animal/))

Forest plot of data evaluating vaginal patency following exposure to K+PFBS in animals. The figure shows percent change from the control response and 95% confidence interval at all exposure doses from Lieder et al. 2009 and Feng et al. 2017. A statistically significant increase is shown at 200 and 500 mg/kg-day from Feng 2017. Results are presented using litter n or fetal n to calculate variability from the Feng et al study. Using litter n results in larger 95% confidence intervals around the mean.

Figure E-7 Kidney Histopathological Effects Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-histopathology-effect-size-animal/))

Bar graph of kidney histopathological effects following exposure to K+PFBS in rodents. The figure shows incidence of focal papillary edema and papillary tubular/ductal epithelium hyperplasia from 0 to 26 at all exposure doses from Lieder et al. 2009a and 2009b. Treatment-related increases in focal papillary edema and papillary tubular/ductal epithelium hyperplasia are observed in male and female rats at 300 mg/kg-day and higher.

Figure E-8 Renal Effects Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-effects-kris-v3/))

Figure E-8 is a dose-response array for studies that evaluated the effects of oral PFBS exposure on the kidney, including blood urea nitrogen (BUN), creatinine, hydronephrosis, focal cortical tubular dilation, right kidney pelvis dilation, focal papillary edema, multifocal tubular basophilia, subacute cortex inflammation, mononuclear cell infiltrate, chronic pyelonephritis, papillary necrosis, tubular degeneration, papillary tubular/ductal epithelium hyperplasia, mineralization, chronic progressive nephropathy, hyaline droplets of cortical tubules, and kidney histopathology. The array is a static representation of information presented in the Health Assessment Workspace Collaborative (HAWC) web platform. The figure shows doses ranging from 0 up to 1,000 mg/kg-day. Where PFBS induced an effect, a red triangle indicates a significant decrease in an endpoint and a green triangle indicates a significant increase. In general, the array shows that oral PFBS exposure leads to increases in focal papillary edema and papillary tubular/ductal epithelium hyperplasia. These were reported in the 2-generation Lieder 2009 study in male and female P0 and F1 rats and the 90 day Lieder 2009 study in male and female rats. No changes in other renal histopathology were reported.

Figure E-9 Kidney-Weight Effects Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-kidney-effects-kris-v3/))

Figure E-9 is a dose-response array for studies that evaluated the effects of oral PFBS exposure on kidney weight. The array is a static representation of information presented in the Health Assessment Workspace Collaborative (HAWC) web platform. The figure shows doses ranging from 0 up to 1,000 mg/kg-day. Where PFBS induced an effect, a red triangle indicates a significant decrease in an endpoint and a green triangle indicates a significant increase. In general, the array shows that oral PFBS does not change absolute or relative kidney weight. Increases were noted in all male rats exposed for 28 days in the NTP 2018 study and for some higher dose groups in 3M 2001.

Figure E-10 Liver Effects Following K^+^PFBS Exposure in Rats

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-liver-effects/))

Figure E-10 is a dose-response array for studies that evaluated the effects of oral PFBS exposure on the liver, including alanine aminotransferase (ALT), aspartate aminotransferase (AST), hepatocyte cytoplasmic alteration, cellular infiltration, mononuclear cell infiltrate, subacute inflammation, focal/multifocal chronic inflammation, hepatocellular hypertrophy, liver necrosis, bile duct cyst, hepatodiaphragmatic nodules, hemorrhage, liver histopathology, absolute liver weight, and relative liver weight. The array is a static representation of information presented in the Health Assessment Workspace Collaborative (HAWC) web platform. The figure shows doses ranging from 0 up to 1,000 mg/kg-day. Where PFBS induced an effect, a red triangle indicates a significant decrease in an endpoint and a green triangle indicates a significant increase. In general, the array shows that oral PFBS does not affect liver endpoints. No changes in liver histopathology were reported. Some studies reported increases in liver weight, including the 28 day study by NTP 2018.

Figure E-11 Effects on Lipids and Lipoproteins Following K^+^PFBS Exposure in Rats and Mice

(Click to see interactive data graphic (https://hawcprd.epa.gov/summary/data-pivot/assessment/100000037/pfbs-lipid-effects/))

Figure E-11 is a dose-response array for studies that evaluated the effects of oral PFBS exposure on lipids and lipoproteins, including apolipoprotein A1 (ApoA1), bile acid secretion, cholesterol ester transfer protein (CETP), cholesterol, cholesterol ester, free cholesterol, free fatty acids, glucose, glycerol, lipoprotein lipase, neutral sterol excretion, triglycerides, VLDL clearance, VLDL half-life, VLDL uptake, VLDL apolipoprotein B (ApoB) secretion rate, VLDL triglyceride secretion rate, and non HDL-cholesterol. The array is a static representation of information presented in the Health Assessment Workspace Collaborative (HAWC) web platform. The figure shows doses ranging from 0 up to 1,000 mg/kg-day. Where PFBS induced an effect, a red triangle indicates a significant decrease in an endpoint and a green triangle indicates a significant increase. In general, the array shows that oral PFBS does not affect lipid endpoints. The study by Bijland 2011 reports statistically significant decreases in CETP, cholesterol ester, free cholesterol, lipoprotein lipase, triglycerides, VLDL half-life, and VLDL apoB secretion rate; as well as an increase in VLDL uptake at 30 mg/kg-day.