# APPENDIX B DETAILED PECO CRITERIA

Table B-1 Population, Exposure, Comparator, and Outcome Criteria

PECO Element | Evidence
Population | Human: Any population (occupational; general population including children, pregnant women, and other sensitive populations). The following study designs will be considered most informative: controlled exposure, cohort, case-control, or cross-sectional. Note: Case reports and case series are not the primary focus of this assessment and will be tracked as supplemental material during the study screening process.; Animal: Nonhuman mammalian animal species (whole organism) of any life stage (including preconception, in utero, lactation, peripubertal, and adult stages).; In vitro models of genotoxicity: The studies will be considered PECO relevant. All other in vitro studies will be tagged as “non-PECO relevant, but supplemental material.”; Nonmammalian model systems/in vitro/in silico NOT related to genotoxicity: Nonmammalian model systems (e.g., fish, amphibians, birds, and Caenorhabditis elegans); studies of human or animal cells, tissues, or biochemical reactions (e.g., ligand binding assays) with in vitro exposure regimens; bioinformatics pathways of disease analysis; and/or high throughput screening data. These studies will be classified as non-PECO relevant, but have supplemental information.
Exposure | Human: Studies providing qualitative or quantitative estimates of exposure based on administered dose or concentration, biomonitoring data (e.g., urine, blood, or other specimens), environmental or occupational-setting measures (e.g., water levels or air concentrations), residential location, job title or other relevant occupational information. Human “mixture” studies are considered PECO relevant as long as they have the PFAS of interest.; Animal: Studies providing qualitative and quantitative estimates of exposure based on administered dose or concentration. Oral and inhalation studies are considered PECO relevant. Nonoral and noninhalation studies are tagged as supplemental. Experimental mixture studies are included as PECO relevant only if they include a PFBS-only arm. Otherwise, mixture studies are tagged as supplemental.; All studies must include exposure to PFBS, CASRN 375-73-5. Studies of precursor PFAS that identify any of the targeted PFAS as metabolites will also be included.
Comparator | Human: A comparison or reference population exposed to lower levels (or no exposure/exposure below detection levels) or for shorter periods of time. For D-R purposes, exposure-response quantitative results must be presented in sufficient detail such as regression coefficients presented with statistical measure of variation such as RR, HR, OR, or SMR or observed cases vs. expected cases (common in occupational studies); slope or linear regression coefficient (i.e., per unit increase in a continuous outcome); difference in the means; or report means with results of t-test, mean comparison by regression, or other mean-comparing hypothesis test.; Animal: Quantitative exposure versus lower or no exposure with concurrent vehicle control group.
Outcome | Cancer and noncancer health outcomes. In general, endpoints related to clinical diagnostic criteria, disease outcomes, histopathological examination, genotoxicity, or other apical/phenotypic outcomes will be prioritized for evidence synthesis. Based on preliminary screening work and other assessments, the systematic review is anticipated to focus on liver (including serum lipids), developmental, reproductive, neurological, developmental neurotoxicity, thyroid disease/disruption, immunological, cardiovascular, and musculoskeletal outcomes.

D-R = dose-response; HR = hazard ratio; OR = odds ratio; PECO = Population, Exposure, Comparator, and Outcome; PFAS = per- and polyfluoroalkyl substances; PFBS = perfluorobutane sulfonic acid; RR = risk ratio; SMR = standardized mortality ratio