# APPENDIX A LITERATURE SEARCH STRATEGY

This appendix presents the full details of the literature search strategy used to identify primary, peer-reviewed literature pertaining to perfluorobutane sulfonic acid (PFBS) (Chemical Abstracts Service registry number [CASRN] 375-73-5) and/or the potassium salt (K^+^PFBS) (CASRN 29420-49-3) and the deprotonated anionic form of PFBS (i.e., PFBS⁻; CASRN 45187-15-3). Initial database searches were conducted on July 18, 2017 using four online scientific databases (PubMed, Web of Science [WOS], TOXLINE, and TSCATS via TOXLINE) and updated on February 28, 2018; May 1, 2019; and May 15, 2020. The literature search focused on chemical name and synonyms (see Table A-1) with no limitations on publication type, evidence stream (i.e., human, animal, in vitro, and in silico) or health outcomes. Beyond database searches, references were also identified from studies submitted under the Toxic Substances Control Act (TSCA) and from review of other government documents (e.g., Agency for Toxic Substances and Disease Registry [ATSDR]) and combined with the results of the database search. Search results are retained in the U.S. EPA’s Health and Environmental Research Online (HERO) database.

Table A-1 Synonyms and MeSH Terms

ChemID | 375-73-5; 1,1,2,2,3,3,4,4,4-Nonafluoro-1-butanesulfonic acid; 1-Perfluorobutanesulfonic acid; Nonafluoro-1-butanesulfonic acid; Nonafluorobutanesulfonic acid; Perfluorobutanesulfonic acid; PFBS; 1,1,2,2,3,3,4,4,4-Nonafluorobutane-1-sulphonic acid
PubMed (new only) | Perfluorobutane sulfonic acid; Perfluorobutanesulfonate; Perfluorobutane sulfonate
EPA Spreadsheet | 1,1,2,2,3,3,4,4,4-Nonafluoro-1-butanesulfonic acid; 1-Butanesulfonic acid, 1,1,2,2,3,3,4,4,4-nonafluoro-; 1-Butanesulfonic acid, nonafluoro-; 1-Perfluorobutanesulfonic acid; Nonafluoro-1-butanesulfonic acid; Nonafluorobutanesulfonic acid; PFBS; Perfluoro-1-butanesulfonate; Perfluorobutane sulfonate; Perfluorobutanesulfonate; Perfluorobutanesulfonic acid; Perfluorobutylsulfonate; 45187-15-3

MeSH = medical subject headings; PFBS = perfluorobutane sulfonic acid.

## A.1 LITERATURE SEARCH STRINGS

### PubMed

375-73-5[rn] OR 45187-15-3[rn] “nonafluorobutane-1-sulfonic acid”[nm] OR “1,1,2,2,3,3,4,4,4-Nonafluoro-1-butanesulfonic acid”[tw] OR “1-Perfluorobutanesulfonic acid”[tw] OR “Nonafluoro-1-butanesulfonic acid”[tw] OR “Nonafluorobutanesulfonic acid”[tw] OR “Perfluorobutanesulfonic acid”[tw] OR “1,1,2,2,3,3,4,4,4-Nonafluorobutane-1-sulphonic acid”[tw] OR “Perfluorobutane sulfonic acid”[tw] OR “Perfluorobutanesulfonate”[tw] OR “Perfluorobutane sulfonate”[tw] OR “1-Butanesulfonic acid, 1,1,2,2,3,3,4,4,4-nonafluoro-”[tw] OR “1-Butanesulfonic acid, nonafluoro-”[tw] OR “Perfluoro-1-butanesulfonate”[tw] OR “Perfluorobutylsulfonate”[tw] OR “Eftop FBSA”[tw] OR (PFBS[tw] AND (fluorocarbon*[tw] OR fluorotelomer*[tw] OR polyfluoro*[tw] OR perfluoro-*[tw] OR perfluoroa*[tw] OR perfluorob*[tw] OR perfluoroc*[tw] OR perfluorod*[tw] OR perfluoroe*[tw] OR perfluoroh*[tw] OR perfluoron*[tw] OR perfluoroo*[tw] OR perfluorop*[tw] OR perfluoros*[tw] OR perfluorou*[tw] OR perfluorinated[tw] OR fluorinated[tw] OR PFAS[tw] OR PFOS[tw] OR PFOA[tw]))

### WOS

TS=“1,1,2,2,3,3,4,4,4-Nonafluoro-1-butanesulfonic acid” OR TS=“1-Perfluorobutanesulfonic acid” OR TS=“Nonafluoro-1-butanesulfonic acid” OR TS=“Nonafluorobutanesulfonic acid” OR TS=“Perfluorobutanesulfonic acid” OR TS=“1,1,2,2,3,3,4,4,4-Nonafluorobutane-1-sulphonic acid” OR TS=“Perfluorobutane sulfonic acid” OR TS=“Perfluorobutanesulfonate” OR TS=“Perfluorobutane sulfonate” OR TS=“1-Butanesulfonic acid, 1,1,2,2,3,3,4,4,4-nonafluoro-” OR TS=“1-Butanesulfonic acid, nonafluoro-” OR TS=“Perfluoro-1-butanesulfonate” OR TS=“Perfluorobutylsulfonate” OR TS=“Eftop FBSA” OR (TS=PFBS AND TS=(fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro-* OR perfluoroa* OR perfluorob* OR perfluoroc* OR perfluorod* OR perfluoroe* OR perfluoroh* OR perfluoron* OR perfluoroo* OR perfluorop* OR perfluoros* OR perfluorou* OR perfluorinated OR fluorinated OR PFAS OR PFOS OR PFOA))

### TOXLINE

( ( 375-73-5 [rn] OR 45187-15-3 [rn] OR “1 1 2 2 3 3 4 4 4-nonafluoro-1-butanesulfonic acid” OR “1-perfluorobutanesulfonic acid” OR “nonafluoro-1-butanesulfonic acid” OR “nonafluorobutanesulfonic acid” OR “perfluorobutanesulfonic acid” OR “1 1 2 2 3 3 4 4 4-nonafluorobutane-1-sulphonic acid” OR “perfluorobutane sulfonic acid” OR “perfluorobutanesulfonate” OR “perfluorobutane sulfonate” OR “1-butanesulfonic acid 1 1 2 2 3 3 4 4 4-nonafluoro-” OR “1-butanesulfonic acid nonafluoro-” OR “perfluoro-1-butanesulfonate” OR “perfluorobutylsulfonate” OR “eftop fbsa” OR ( pfbs AND ( fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro* OR perfluorinated OR fluorinated OR pfas OR pfos OR pfoa ) ) ) ) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]

### TSCATS

375-73-5[rn] AND tscats[org]; 45187-15-3[rn] AND tscats[org]