# COMMONLY USED ABBREVIATIONS AND ACRONYMS

AEC: absolute eosinophil count
AFFF: aqueous film-forming foam
AIC: Akaike’s information criterion
ALT: alanine aminotransferase
AST: aspartate aminotransferase
AUC: area under the curve
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
CA: chromosomal aberration
CASRN: Chemical Abstracts Service registry number
CHO: Chinese hamster ovary (cell line)
CI: confidence interval
CPHEA: Center for Public Health and Environmental Assessment
CPN: chronic progressive nephropathy
D3: deiodinase 3
DAF: dosimetric adjustment factor
DNA: deoxyribonucleic acid
ECP: eosinophilic cationic protein
GD: gestation day
GLP: Good Laboratory Practice
HAWC: Health Assessment Workspace Collaborative
HED: human equivalent dose
HPT: hypothalamic-pituitary-thyroid
i.v.: intravenous
ICR: Institute of Cancer Research
K^+^PFBS: potassium perfluorobutane sulfonate
k_elim_: serum elimination rate constant
LD: lactation day
LD_50_: median lethal dose
LOAEL: lowest-observed-adverse-effect level
MW: molecular weight
NHANES: National Health and Nutrition Examination Survey
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
NZW: New Zealand White (rabbit breed)
OR: odds ratio
PECO: Population, Exposure, Comparator, and Outcome
PFAA: perfluoroalkyl acid
PFAS: per- and polyfluoroalkyl substances
PFBS: perfluorobutane sulfonic acid
PFHxA: perfluorohexanoic acid
PFOA: perfluorooctanoic acid
PFOS: perfluorooctane sulfonic acid
PND: postnatal day
POD: point of departure
RfC: inhalation reference concentration
RfD: oral reference dose
ROS: reactive oxygen species
rT_3_: reverse triiodothyronine
S-D: Sprague-Dawley
SD: standard deviation
T_2_: 3,5-diiodo-L-thyronine
T_3_: triiodothyronine
T_4_: thyroxine
TBG: thyroid-binding globulin
TSH: thyroid-stimulating hormone
TTR: transthyretin
UF: uncertainty factor
UF_A_: interspecies uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: database uncertainty factor
UF_H_: intraspecies uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
U.S. EPA: U.S. Environmental Protection Agency
VLDL: very low-density lipoprotein