# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

No studies were located regarding toxicity of perylene to humans or animals via oral exposure. Due to the lack of oral toxicity data for perylene, subchronic and chronic provisional reference doses (p-RfDs) were not derived directly. Instead, screening subchronic and chronic p-RfDs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, BaP was selected as the most appropriate analogue for perylene for deriving screening subchronic and chronic p-RfDs (see Table 5).

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

No studies were located regarding toxicity of perylene to humans or animals via inhalation exposure. Due to the lack of inhalation toxicity data for perylene, subchronic and chronic provisional reference concentrations (p-RfCs) were not derived directly. Instead, screening subchronic and chronic p-RfCs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, BaP was selected as the most appropriate analogue for perylene for deriving screening subchronic and chronic p-RfCs (see Table 5).

## 3.3 SUMMARY OF NONCANCER SCREENING PROVISIONAL REFERENCE VALUES

The noncancer screening provisional reference values for perylene are summarized in Table 5.

Table 5 Summary of Noncancer Reference Values for Perylene (CASRN 198-55-0)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) | Rat/M, F | Neurobehavioral effects following early postnatal exposure | 9 × 10^−5^ | BMDL_1SD_ | 0.092^a^ (based on analogue POD) | 1,000 | Chen et al. (2012); U.S. EPA (2017a)
Screening chronic p-RfD (mg/kg-d) | Rat/M, F | Neurobehavioral effects following early postnatal exposure | 9 × 10^−5^ | BMDL_1SD_ | 0.092^a^ (based on analogue POD) | 1,000 | Chen et al. (2012); U.S. EPA (2017a)
Screening subchronic p-RfC (mg/m^3^) | Rat/F | Decreased embryo/fetal survival | 2 × 10^−6^ | LOAEL | 0.0046 (based on analogue POD) | 3,000 | Archibong et al. (2002); U.S. EPA (2017a)
Screening chronic p-RfC (mg/m^3^) | Rat/F | Decreased embryo/fetal survival | 2 × 10^−6^ | LOAEL | 0.0046 (based on analogue POD) | 3,000 | Archibong et al. (2002); U.S. EPA (2017a)

a The POD was not converted into a HED using BW^3/4^ because it is unknown whether allometric scaling is appropriate for exposure in early postnatal animals (see Appendix A for more details).

BMDL = benchmark dose lower confidence limit; BW = body weight; F = female(s); HEC = human equivalent concentration; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; M = male(s); POD = point of departure p-RfC = provisional inhalation reference concentration; p-RfD = provisional oral reference dose; SD = standard deviation; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Although the scientific literature provides limited information on the mutagenicity and genotoxicity of perylene, no oral or inhalation studies have been conducted to assess its carcinogenicity. Available dermal studies and a single i.p. carcinogenicity study provide limited evidence of carcinogenic potential; the relevance of these findings to oral or inhalation exposure is unclear. Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is “Inadequate Information to Assess Carcinogenic Potential” of perylene by oral or inhalation exposure (see Table 6).

Table 6 Cancer WOE Descriptor for Perylene (CASRN 198-55-0)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | No human data are available.
“Likely to be Carcinogenic to Humans” | NS | NA | No adequate chronic animal cancer bioassays are available.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | No adequate chronic animal cancer bioassays are available.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | No adequate chronic animal cancer bioassays are available. Dermal and i.p. studies in animals provide limited evidence of carcinogenic potential.
“Not Likely to be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity following oral or inhalation exposure is available. No adequate chronic animal cancer bioassays are available.

i.p. = intraperitoneal; NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

Due to inadequate information to assess carcinogenic potential, quantitative cancer risk estimates could not be derived for perylene (see Table 7).

Table 7 Summary of Cancer Risk Estimates for Perylene (CASRN 198-55-0)

Toxicity Type | Species/Sex | Tumor Type | Cancer Value | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.