# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

As summarized in Tables 3A and 3B, no short-term, subchronic, chronic, or reproductive/developmental toxicity studies of perylene in humans or animals exposed by oral or inhalation routes adequate for deriving provisional toxicity values have been identified. The phrase “statistical significance,” used throughout the document, indicates a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for Perylene (CASRN 198-55-0)

Category | Number of Male/Female, Strain Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | NOAEL | LOAEL | Reference (comments) | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

LOAEL = lowest-observed-adverse-effect level; ND = no data; NOAEL = no-observed-adverse-effect level.

Table 3B Summary of Potentially Relevant Cancer Data for Perylene (CASRN 198-55-0)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference (comments) | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

## 2.1 HUMAN STUDIES

Studies directly examining the toxicity or carcinogenicity of perylene in humans were not located. Perylene is a component of complex PAH-containing combustion product mixtures, several of which are known or suspected to be carcinogenic in humans (e.g., coal tars, soot, and tobacco smoke and products) (IARC, 1998, 1983). However, results from studies of these mixtures do not provide adequate exposure data for dose-response assessment to derive toxicity values for perylene or other individual PAH components.

## 2.2 ANIMAL STUDIES

No studies were located regarding cancer or noncancer effects in animals after oral or inhalation exposure.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

Available toxicity data for perylene are limited to dermal and injection studies in laboratory animals evaluating immunotoxicity and carcinogenicity. Other available data include toxicokinetic studies and genotoxicity assays.

### 2.3.1 Genotoxicity

The genotoxicity of perylene has been examined in numerous in vitro studies and a very limited number of in vivo studies. Available studies are summarized in Table 4A. The data indicate that perylene is mutagenic in bacteria in the presence of metabolic activation and is usually less mutagenic in the absence of metabolic activation. In cultured human cell lines, perylene was not mutagenic with endogenous or exogenous metabolic activity. In general, perylene did not cause chromosomal damage in vitro or in host-mediated assays, and there is no evidence that perylene directly damages or binds deoxyribonucleic acid (DNA). Perylene induced cell transformation in metabolically competent mouse cells but did not induce cell transformation in hamster cells in the absence of metabolic activation (see Table 4A).

Table 4A Summary of Perylene Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References
Genotoxicity studies in prokaryotic organisms
Reverse mutation | Salmonella typhimurium TA98, TA100, TA1535, TA1538 | 4–2,500 μg/plate | NDr | + (TA1535, TA100); − (TA98, TA1538) | Plate incorporation method. Perylene was positive in TA1535 and TA100 in the presence of metabolic activation under conditions in which background lawn indicated at least 10% survival. The maximum increase in revertants observed was a 20-fold increase at 100 μg/plate in TA1535 and a 5-fold increase at 4 μg/plate in TA100 (quantitative data not reported at other concentrations). Perylene was negative in TA98 and TA1538. No details were provided regarding compound solubility in the test medium. | Anderson and Styles (1978)
Reverse mutation | S. typhimurium TA98 | NS | − | − | Plate incorporation method. No increase in revertants was observed with or without metabolic activation. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Anderson et al. (1987)
Reverse mutation | S. typhimurium TA98, TA100 | 50 μg/plate | NDr | + | Plate incorporation method. Perylene was positive with metabolic activation in TA98 and TA100. Mutagenic activity increased with increasing concentration of rat liver S9 (ranged from 5 to 420 μL/plate) with a >twofold increase in revertants at S9 concentrations ≥60 μL/plate. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Carver et al. (1985)
Reverse mutation | S. typhimurium TA100 | 5, 10, 15 μg/plate | NDr | + | Plate incorporation method. Perylene was positive with metabolic activation. Mutagenic activity increased with increasing rat and hamster liver S9, with a >twofold increase in revertants at all S9 concentrations (ranged from 50 to 400 μL/plate). Perylene-specific data on cell survival or compound solubility in the test medium were not reported, but the study authors indicated that compounds were tested to limit of solubility, of cytotoxicity, or to 1,000 μg/plate. | Carver et al. (1986)
Reverse mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | NS (serial twofold dilution series starting at a high concentration of solubility or toxicity limit) | NDr | + (TA98, TA1537, TA1538); ± (TA100); − (TA1535) | Plate incorporation method. Perylene was positive in TA98, TA1537, and TA1538 (>2-fold increase in revertants) and weakly positive in TA100 (1.5- to 2-fold increase in revertants) in the presence of metabolic activation. Perylene was negative in TA1535. Perylene-specific data on cell survival or compound solubility in the test medium were not reported, but the study authors indicated that the highest dose tested was based on solubility or toxicity limit. | De Flora et al. (1984)
Reverse mutation | S. typhimurium TA97, TA98, TA100, TA1535, TA1537, TA1538 | 40–80 nmol/plate | ± TA100; − (TA97, TA98, TA1535, TA1537, TA1538) | ± (strain[s] NS) | Plate incorporation method. Perylene was weakly positive (1.9-fold increase in revertants) in TA100 without metabolic activation. The addition of metabolic activation was “borderline activating” (no additional details or strain-specific information were reported). Perylene-specific data on cell survival or compound solubility in the test medium were not reported, but the study authors indicated that the highest dose tested was based on solubility or toxicity limit. | De Flora (1981)
Reverse mutation | S. typhimurium TA98, TA100 | Up to 0.75 μmol/plate | ± (strain NS) | + (TA98); − (TA100) | Plate incorporation method. Perylene was positive in TA98 and negative in TA100 with metabolic activation. Perylene was noted to be “weakly mutagenic” without metabolic activation, but the magnitude of response and strain were not specified. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Florin et al. (1980)
Reverse mutation | S. typhimurium TA97 | Up to 400 nmol/plate | NDr | − | Liquid test and plate incorporation methods. No increase in revertants was observed with metabolic activation by either method. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Hera and Pueyo (1988)
Reverse mutation | S. typhimurium TA98 | 0.001–0.020 mg/plate | NDr | + | Plate incorporation method. Revertants were increased two- to sixfold in TA98 in the presence of metabolic activation. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Ho et al. (1981)
Reverse mutation | S. typhimurium TA100, TA98 | 10 or 20 μg/plate | NDr | + (TA100); − (TA98) | Plate incorporation method. Revertants were increased two- to threefold in TA100 in the presence of metabolic activation. No evidence of mutagenicity was observed in TA98 with metabolic activation. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Lavoie et al. (1979)
Reverse mutation | S. typhimurium TA98, TA100 | 1–40 μg/plate | − | + | Plate incorporation method. Perylene was positive in TA98 and TA100 in the presence of metabolic activation and negative in the absence of metabolic activation. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Lofroth et al. (1984)
Reverse mutation | S. typhimurium TA97, TA98, TA100 | 1–50 μg/plate | − | + | Plate incorporation method. Revertants increased >twofold at all concentrations in TA97 and at ≥4 μg/plate in TA98 and TA100 with metabolic activation. No evidence of mutagenicity was observed without S9 activation. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Sakai et al. (1985)
Reverse mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0.1–1,000 μg/plate | − | − | Plate incorporation method. Revertants were increased <twofold in all strains with or without metabolic activation. Perylene-specific data on cell survival or compound solubility in the test medium were not reported, but (when observed) the study authors discussed cytotoxicity and solubility issues identified with other tested compounds. | Salamone et al. (1979)
Forward mutation | S. typhimurium BA9 | Up to 400 nmol/plate | NDr | + | L-arabinose resistance assay. Perylene significantly increased the frequency of L-arabinose-resistant mutants in strain BA9 in the presence of a high concentration (33%) of S9; findings were not significant at 3% S9. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Hera and Pueyo (1988)
Forward mutation | S. typhimurium TM677 | 1.1 μM | NDr | + | 8-Azaguanine resistance assay. Perylene was mutagenic at the 8AG^s^/8AG^r^ locus. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Kaden et al. (1979)
Forward mutation | S. typhimurium TM677 | 2.6–40 μM | − | + | 8-Azaguanine resistance assay. Perylene increased mutation rates for 8-azaguanine resistance in the presence of metabolic activation. Cell survival was >80% at all tested concentrations. No details were provided regarding compound solubility in the test medium. | Penman et al. (1980)
Forward mutation | S. typhimurium TM677 | Up to 80 μM | NDr | + | 8-Azaguanine resistance assay. Perylene increased mutation rates for 8-azaguanine resistance in the presence of metabolic activation. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Thilly et. al. (1983)
DNA damage | Escherichia coli PQ37 | 0.156–10 μg/assay | − | − | SOS chromotest. Perylene was negative for DNA damage with or without metabolic activation. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Mersch-Sundermann et. al. (1992)
DNA damage | E. coli PQ37 | Three to five concentrations at half-log intervals up to limit of solubility or 100 mM | − | NDr | SOS chromotest. Criterion for positive response was not reported. Perylene was negative for DNA damage without metabolic activation. Perylene-specific data on cell survival or compound solubility in the test medium were not reported, but the study authors indicated that the highest dose tested was based on solubility limit (up to 100 mM). | von der Hude et al. (1988)
DNA repair | E. coli WP2, WP67, CM871 | ≤50 μg (eight twofold dilutions) | − | − | Liquid micromethod. The minimal inhibitory concentration was >50 μg with or without metabolic activation. Perylene-specific data on cell survival or compound solubility in the test medium were not reported, but the study authors indicated that the highest dose tested was based on solubility or toxicity limit. | De Flora et al. (1984)
DNA repair | E. coli WP2, WP67, CM871 | ≤50 μg/10^3^ bacteria | − | ± | 2-H preincubation assay (treat-and-plate method). Survival did not differ between repair-deficient and wild-type strains without metabolic activation. Findings were equivocal with metabolic activation. No details were provided regarding compound solubility in the test medium. | De Flora et al. (1984)
Genotoxicity studies in mammalian cells—in vitro
Mutation | Human lymphoblast cell line (AHH-1) | 10 or 20 μM | − | NA | Forward mutation assay (6-thioguanine-resistance assay). There was no evidence of mutagenicity without exogenous metabolic activation (AHH-1 cells have endogenous metabolic capabilities). No cytotoxicity was observed. Concentrations >20 μM were not tested due to solubility issues. | Crespi and Thilly (1984)
Mutation | Human lymphoblast cell line (h1A1v2) | 1–10,000 ng/mL | − | NA | Forward mutation assay (thymidine kinase locus). There was no evidence of mutagenicity without exogenous metabolic activation (h1A1v2 cells constitutively express cytochrome P4501A1). Cell survival was >75% at all tested concentrations. No details were provided regarding compound solubility in the test medium. | Durant et al. (1996)
Mutation | Human diploid lymphoblast cells | 11 or 22 μM | NDr | − | Forward mutation assay (6-thioguanine-resistance assay). There was no evidence of mutagenicity with exogenous metabolic activation. No details were provided regarding compound solubility in the test medium. | Penman et al. (1980)
Mutation | Human diploid lymphoblast cells | 11 or 22 μM | NDr | − | Forward mutation assay (thymidine kinase locus). There was no evidence of mutagenicity with exogenous metabolic activation. No details were provided regarding compound solubility in the test medium. | Penman et al. (1980)
CAs | Human peripheral leukocytes | 10 μg/mL | − | NDr | There was no induction of CAs without metabolic activation. Of the metaphases scored in cells exposed to perylene, 0/200 showed chromosomal G bands (no other aberration types were scored). No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | DiPaolo and Popescu (1974)
CAs | SHE cells | 10 μg/mL | − | NDr | There was no induction of CAs without metabolic activation. Of the metaphases scored in cells exposed to perylene, 0/200 showed chromosomal G bands (no other aberration types were scored). No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | DiPaolo and Popescu (1974)
CAs | Chinese hamster V79 cells | 10 μg/mL | + | NDr | Perylene increased the frequency of CAs (dicentric chromosomes, chromatid gaps, chromatid interchanges) without metabolic activation. The number of cell metaphases showing at least one aberration was 9/20 for perylene, compared to 0/20 for control. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Popescu et al. (1977)
SCE | Chinese hamster V79 cells | 10 μg/mL | − | NDr | There was no induction of SCE without metabolic activation. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Popescu et al. (1977)
Unscheduled DNA synthesis | SHE cells | 20 μg/mL | − | NDr | There was no induction of unscheduled DNA synthesis without metabolic activation. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Casto et al. (1976)
DNA synthesis | Sprague Dawley rat primary hepatocytes | 0.01–100 nM | − | NDr | 3H-thymidine incorporation assay. Perylene did not induce DNA synthesis. Perylene was not tested at concentrations >100 nM due to cytotoxicity. No details were provided regarding compound solubility in the test medium. | Zhao and Ramos (1995)
Cell transformation | Bhas 42 cells (v-Ha-ras-transfected BALB/c 3T3 cell line) | 0.01–10 μg/mL | + | NA | Initiation/promotion transformation assay. Perylene significantly increased the number of transformation foci/well in both the initiation stage of the assay (2-d treatment of low-density cells; ≥1 μg/mL) and promotion stage of the assay (12-d treatment of near confluent cells; ≥0.1 μg/mL) without exogenous metabolic activation (Bhas 42 cells have endogenous metabolic capabilities). No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Asada et al. (2005)
Cell transformation | SHE cells | Up to 20 μg/mL | − | NDr | Pretreatment with perylene did not increase transformation frequency associated with adenovirus infection. No cytotoxicity was observed. No details were provided regarding compound solubility in the test medium. | Casto et al. (1973)
Cell transformation | SHE cells | 20 μg/mL | − | NDr | Perylene did not increase transformation frequency. When a promotor (TPA) was added 48 h after incubation with perylene, the percentage of transformed colonies was 0.54%. Cloning efficiency was comparable to control. No details were provided regarding compound solubility in the test medium. | Popescu et al. (1980)
DNA adducts/binding | Human peripheral blood lymphocytes | 30 μM | − | NDr | ^32^P-postlabeling analysis. No DNA adducts were detected in cells after perylene exposure. No details were provided regarding cytotoxicity or compound solubility in the test medium. | Gupta et al. (1988)
Genotoxicity studies—mammalian species in vivo
SCE | Chinese hamster V79 cells implanted in mouse (C3H/St) peritoneal cavity; mice were injected with perylene after implantation | NS | − | NA | Host-mediated SCE assay. V79 cells were contained in diffusion chambers implanted in the peritoneal cavities of mice; V79 cells were examined for SCE frequencies after perylene injection (additional treatment details not reported). No increases of SCE frequency were detected with perylene compared to controls. | Sirianni and Huang (1978)
DNA adducts | Female BALB/c mice exposed via four topical applications at 0, 6, 30, and 54 h; sacrificed 24 h after last treatment | 1.2 μmol | − | NA | ^32^P-postlabeling analysis. No adducts were detected in mouse skin. | Reddy et al. (1984)

a + = positive; ± = weakly positive/equivocal; − = negative.

CA = chromosomal aberration; DNA = deoxyribonucleic acid; NA = not applicable; NDr = not determined; NS = not specified; SHE = Syrian hamster embryo; SCE = sister chromatid exchange; TPA = 12-O-tetradecanoylphorbol 13-acetate.

#### Mutagenicity

Of the available reverse mutation studies in Salmonella typhimurium, 10/13 reported that perylene was at least weakly mutagenic in the presence of metabolic activation in one or more strains (Carver et al., 1986, 1985; Sakai et al., 1985; De Flora et al., 1984; Lofroth et al., 1984; De Flora, 1981; Ho et al., 1981; Florin et al., 1980; Lavoie et al., 1979; Anderson and Styles, 1978) (see Table 4A). In general, perylene induced borderline or low reverse mutation rates in comparison to other mutagens (e.g., other PAHs) (Hera and Pueyo, 1988; Carver et al., 1986; De Flora et al., 1984; Lofroth et al., 1984; De Flora, 1981; Ho et al., 1981; Florin et al., 1980; Anderson and Styles, 1978). Three studies indicated that perylene was not mutagenic with metabolic activation (Hera and Pueyo, 1988; Anderson et al., 1987; Salamone et al., 1979). Two of these studies [Anderson et al. (1987) and Hera and Pueyo (1988)] used low concentrations of S9 (2–3%), which may have been inadequate to promote metabolic transformation; however, Salamone et al. (1979) reported negative results with 10% S9. Perylene also induced forward mutations in S. typhimurium strains in the presence of metabolic activation (Hera and Pueyo, 1988; Thilly et al., 1983; Penman et al., 1980; Kaden et al., 1979). In contrast to reverse mutations, the forward mutagenic potential of perylene in the 8-azaguanine resistance assay was similar or more potent compared to other PAHs (e.g., benzo[a]pyrene [BaP]) (Thilly et al., 1983; Penman et al., 1980; Kaden et al., 1979). In the absence of metabolic activation, perylene did not induce reverse mutations in S. typhimurium in four of six assays (Anderson et al., 1987; Sakai et al., 1985; Lofroth et al., 1984; Salamone et al., 1979) and was weakly mutagenic in one or more strains in two of six assays (De Flora, 1981; Florin et al., 1980). Perylene did not induce forward mutations in S. typhimurium in the absence of metabolic activation (Penman et al., 1980).

Perylene was not mutagenic in metabolically competent human cell lines (Durant et al., 1996; Crespi and Thilly, 1984) or in human cell lines with exogenous metabolic activation (Penman et al., 1980).

#### Clastogenicity

Evidence from in vitro studies in mammalian cells regarding clastogenicity is mostly negative. Sister chromatid exchanges (SCEs) were not observed in Chinese hamster V79 cells in the absence of metabolic activation (Popescu et al., 1977). Similarly, chromosomal aberrations (CAs), specifically chromosomal G bands, were not observed during metaphase in human peripheral lymphocytes or Syrian hamster embryonic (SHE) cells in the absence of metabolic activation (Popescu et al., 1977; DiPaolo and Popescu, 1974). However, the frequency of CAs was increased in Chinese hamster V79 cells without metabolic activation, including dicentric chromosomes, chromatid gaps, and chromatid interchanges (Popescu et al., 1977). None of the in vitro clastogenicity studies were conducted in the presence of metabolic activation. In a host-mediated assay, SCEs were not observed in Chinese hamster V79 cells implanted into the peritoneal cavity of mice prior to perylene injection (Sirianni and Huang, 1978).

#### DNA Damage and Repair

Findings were generally negative in in vitro assays of DNA damage and repair. In Escherichia coli, perylene did not induce DNA damage or repair without metabolic activation; with activation, findings were negative or equivocal/borderline (Mersch-Sundermann et al., 1992; von der Hude et al., 1988; De Flora et al., 1984). In mammalian cells, perylene did not induce DNA synthesis in Sprague Dawley rat primary hepatocytes or unscheduled DNA synthesis in SHE cells in the absence of metabolic activation; assays were not conducted in the presence of metabolic activation (Zhao and Ramos, 1995; Casto et al., 1976).

Perylene did not form DNA adducts in cultured human peripheral blood lymphocytes (Gupta et al., 1988). Similarly, no DNA adducts were identified in mouse skin following repeated topical application of perylene to shaved skin of mice (four exposures over 54 hours) (Reddy et al., 1984).

#### Cell Transformation

Perylene did not induce cell transformation in SHE cells in the absence of metabolic activation (Popescu et al., 1977; Casto et al., 1973). In an assay specifically designed to evaluate tumor initiation and promotion potentials of compounds, perylene induced transformation foci in metabolically competent Bhas 42 cells (derived from BALB/c mouse 3T3 cells) in both initiation and promotion stages (Asada et al., 2005).

### 2.3.2 Supporting Studies in Animals

#### Immunotoxicity

Humoral immunity in mice was not suppressed following subcutaneous (s.c.) injection of perylene for 1 or 14 days (see Table 4B), as measured by antibody responses to an antigen (sheep red blood cells [sRBCs]) in a plaque-forming cell (PFC) assay (White et al., 1985). The study also evaluated spleen weight, spleen cellularity, and thymus weight, and observed no statistically significant changes. A statistically significant increase in body weight was reported following a 14-day exposure to perylene. This study compared the response of perylene to the robust immunosuppressive response of BaP administered at the same dose level (40 mg/kg-day). It is unclear whether perylene would have elicited an immunosuppressive response if given at higher doses, for a longer duration, or via a different route of exposure. No additional in vivo studies evaluating immunotoxicity were identified. In an in vitro assay in human skin keratinocytes, perylene induced dose-dependent inflammatory cytokine secretion (interleukin-1α, interleukin-6) (Bahri et al., 2010).

Table 4B Other Supporting Studies of Perylene

Test | Materials and Methods | Results | Conclusions | References
Immunotoxicity in vivo studies
T-cell-dependent antibody response study by s.c. injection | Female B6C3F1 mice (n = 8); daily s.c. injections containing 0 (com oil vehicle) or 40 mg/kg-d (160 μmol/kg-d) for 1 or 14 d; spleen IgM response was evaluated 4 d after injection with sRBCs (body weight, spleen weight, thymus weight, cellularity, and number of PFCs). | No change in the spleen IgM response to sRBCs. No change in spleen or thymus weight or spleen cellularity. A statistically significant increase (~34%) in body weight was reported after the 14-d exposure. | Perylene did not impair humoral immunity in mice under the conditions of this study. | White et al. (1985)
Immunotoxicity in vitro studies
Cytokine release and cytotoxicity in human keratinocytes | Keratinocytes (Clonetics) were dosed at various concentrations (1, 2, 5, 10, or 15 μM) with perylene, methylpyrene, or both dissolved in sodium dodecyl sulfate for 24 h–9 d (depending on endpoint). Cells were assessed for viability, colony forming efficiency, scrape-wound healing assay, apoptosis/necrosis, and cytokine secretion. | At the lowest tested concentration (1 μM), perylene decreased keratinocyte adhesion and viability in a concentration-dependent manner. Perylene reduced keratinocyte colony formation, and increased apoptosis. Interleukin-1α and interleukin-6 levels were significantly increased with increasing exposure to perylene (>2 μM). Toxicity was enhanced when perylene and methylpyrene were assessed as a mixture. | Perylene induced dose-dependent increases in inflammatory cytokine secretion and exerted a cytotoxic effect on human keratinocytes. | Bahri et al. (2010)
Carcinogenicity in vivo studies
Dermal complete carcinogenicity study | Male C3H mice (n = 20); 60 μL of a 0.15% perylene solution in decalin per application; 2 times/wk for up to 82 wk. An appropriate negative control group was not included. BaP (0.14%) was used as a positive control. | [underlined: Skin tumors]; Perylene: 0/16 (0%); Positive control (BaP): 15/21 (71%) (10 papillomas, 5 carcinomas); Note: Incidence is based on the number of mice alive at least 52 wk. | Perylene was not carcinogenic under the conditions of this study. | Horton and Christian (1974)
Dermal complete carcinogenicity study | Male Swiss mice (n = 20); 0.3% perylene in benzene every 4 d for up to 24 wk; a benzene-only vehicle control group was not included. BaP (0.3%) was used as a positive control. | [underlined: Skin tumors (unspecified)]; Perylene: 0/20 (0%); Positive control (BaP): 36/40 (90%) | Perylene was not carcinogenic under the conditions of this study. | Finzi et al. (1968)
Dermal complete carcinogenicity and initiation-promotion studies | Female CD-1 mice (number/group not specified); dermal application of 0 or 1% perylene 3 times/wk for 1 yr (vehicle not reported); a separate group of mice were initiated with a single 300 μg dermal dose of BaP followed by dermal application of 1% perylene 3 times/wk for 1 yr. | No increase in skin tumors in perylene or BaP + perylene treated mice, compared to vehicle control (incidence data not reported). | Perylene was not a complete carcinogen or tumor promotor under the conditions of this study. Data reporting is too limited for independent review (abstract only). | Anderson and Anderson (1987)
Dermal initiation-promotion study | Female Crl/CD-1(ICR)BR mice (n = 20); dermal application of 1 mg perylene in acetone applied in 10 doses (every other day), followed by 2.5 μg TPA in 0.1 mL acetone 3 times/wk for 25 wk; the vehicle control group was acetone with TPA promotion. BaP (0.05 mg) was used as a positive control. | [underlined: Skin tumors (“predominantly” papillomas)]; Acetone + TPA: 1/20 (5%); Perylene + TPA: 1/20 (5%); Positive control (BaP + TPA): 18/20 (90%) | Perylene was not a tumor initiator under the conditions of this study. | El-Bayoumy et al. (1982)
Dermal initiation-promotion study | Female ICR/Ha Swiss mice (n = 20); single dermal application of 800 μg perylene in benzene followed by 2.5 μg TPA in 0.1 mL acetone 3 times/wk for 58–60 wk; four control groups were used: untreated, acetone, perylene initiating dose only, and TPA-only (with no initiator). A benzene vehicle control was not included. DMBA (20 μg in acetone) was used as a positive control. | [underlined: Skin tumors]; Untreated control: 0/20 (0%); Acetone control: 0/20 (0%); Perylene only: 0/20 (0%); TPA only: 1/20 (5%); (1 papilloma); Perylene + TPA: 3/20 (15%); (3 papillomas); Positive control (DMBA + TPA): 19/20 (95%); (13 carcinomas, 6 papillomas) | Perylene was not a tumor initiator under the conditions of this study. Perylene may be a weak tumor initiator; papilloma incidence was slightly increased compared to controls but did not reach statistical significance. | Van Duuren et al. (1970)
Dermal cocarcinogenicity study | Male C3H mice (n = 20); 60 μL of a 0 or 0.15% perylene solution in a 50:50 decalin:dodecane (De:Do) vehicle per application; 2 times/wk for up to 82 wk. BaP (0.14%) was used as a positive control using 100:0, 80:20, or 60:40 De:Do vehicle. Dodecane was selected as the cocarcinogen because it had previously been shown to be a skin cocarcinogen with benz[a]anthracene but is not a skin carcinogen when administered alone. | [underlined: Skin tumors]; Vehicle control: 2/13 (15%); (2 papillomas); Perylene: 1/15 (7%); (1 papilloma); Positive control (BaP): 100% decalin: 15/21 (71%); (5 carcinomas, 10 papillomas); 80:20 De:Do: 13/15 (87%); (6 carcinomas; 7 papillomas); 60:40 De:Do: 15/15 (100%); (15 carcinomas); Note: Incidence is based on the number of mice alive at least 52 wk. | Perylene was not cocarcinogenic (with dodecane) under the conditions of this study. | Horton and Christian (1974)
Dermal tumor inhibition study | Male Swiss mice (n = 40); 0.3% BaP in benzene or 0.3% perylene and 0.3% BaP in benzene every 4 d for up to 24 wk. | [underlined: Skin papillomas]; BaP: 36/40 (90%); BaP + perylene: 13/40 (30%) | Perylene inhibited the tumorigenic response of BaP under the conditions of this study. Statistical analysis of results was not performed by the study authors. | Finzi et al. (1968)
Lung tumor study by i.p. injection | Strain A mice (sensitive model for lung tumor induction); i.p. injection of 0, 200, 500, or 1,000 mg/kg perylene 3 times/wk for 8 wk followed by a 16-wk observation period. | No increase in lung adenomas compared to control (vehicle not reported; incidence data not reported). | Perylene did not induce lung tumors under the conditions of this study. Data reporting is too limited for independent review (abstract only). | Anderson and Anderson (1987)

BaP = benzo[a]pyrene; DMBA = 7,12-dimethylbenz[a]anthracene; IgM = immunoglobulin M; i.p. = intraperitoneal; n = number; s.c. = subcutaneous; sRBC = sheep red blood cell; PFC = plaque forming colony; TPA = 12-O-tetradecanoylphorbol acetate.

#### Cancer

Available skin painting studies (see Table 4B), while limited by design flaws (lack of negative controls, potentially inadequate dose levels, small group sizes) and/or limited reporting (abstract only), do not indicate that perylene is a complete dermal carcinogen or cocarcinogen. No skin tumors were observed in 16 mice following exposure to 0.15% perylene twice weekly in a decalin vehicle for up to 82 weeks; in contrast, the same protocol with 0.14% BaP induced skin tumors (Horton and Christian, 1974). Similarly, no skin tumors were observed in 20 mice exposed to 0.3% perylene in benzene every 4 days for up to 24 weeks, while exposure to 0.3% BaP induced skin tumors using the same protocol (Finzi et al., 1968). In a study only available as an abstract, dermal application of 1% perylene (vehicle not reported) 3 times weekly for 1 year did not increase the number of skin tumors, compared to vehicle control (incidence data not reported) (Anderson and Anderson, 1987).

Skin tumor initiation-promotion studies do not indicate that perylene is a strong tumor initiator or promotor. Perylene was not a mouse skin tumor initiator following single exposure (800 μg in benzene) or 10 repeated exposures (total dose 1 g in acetone) with 12-O-tetradecanoylphorbol-13 acetate (TPA) as a promotor (El-Bayoumy et al., 1982; Van Duuren et al., 1970). In both studies, the positive control group (BaP or 7,12-dimethylbenz[a]anthracene) showed expected tumor-initiating activity. In a study only available as an abstract, perylene was not a tumor promotor when applied as a 1% solution (vehicle not reported) 3 times weekly for 1 year following a single initiating dose of 300 μg BaP (Anderson and Anderson, 1987).

Two dermal studies also evaluated carcinogenic potential of perylene in the presence of other chemicals. Horton and Christian (1974) evaluated cocarcinogenic potential of 0.15% perylene twice weekly in a decalin/dodecane vehicle (50:50 ratio). Dodecane had previously been shown to be a skin cocarcinogen with benz[a]anthracene, but is not a skin carcinogen when administered alone (Horton and Christian, 1974). Animals coexposed to perylene did not have significantly increased skin papillomas (1/15) compared with animals exposed only to decalin/dodecane (2/13). In contrast, BaP and dodecane showed evidence of cocarcinogenicity following a similar protocol (Horton and Christian, 1974). In a study by Finzi et al. (1968), perylene coexposure decreased the number of skin tumors induced by BaP (13/40) compared to BaP alone (36/40); however, statistical analysis of the data was not performed. The study authors proposed that perylene prevented BaP-induced tumor formation via competitive binding to epidermal proteins.

In a study only available as an abstract, intraperitoneal (i.p.) injections of perylene at doses of 200–1,000 mg/kg 3 times/week for 8 weeks did not induce lung tumors in Strain A mice, a sensitive model for detecting lung tumor induction, following a 16-week postexposure observation period (Anderson and Anderson, 1987). Due to the limitations of these available injection and dermal cancer studies, it is not possible to thoroughly assess perylene’s carcinogenic potential following oral and inhalation exposures.

### 2.3.3 Metabolism/Toxicokinetic Studies

There is limited information available on in vivo toxicokinetics or metabolism of perylene. A single study evaluated metabolism in rat subcutaneous tissue following s.c. injection of various PAHs (Flesher and Myers, 1990). In this study, perylene did not show any evidence of bioalkylation or metabolism within subcutaneous tissue. In contrast, a weakly carcinogenic PAH, benz[a]anthracene, showed evidence of bioalkylation substitution reactions in rat subcutaneous tissue. Other tissues in the body were not evaluated for parent compound or metabolite levels in this study. No other studies were identified to evaluate in vivo toxicokinetics or metabolism of perylene. Because absorption and distribution of a chemical in the body are determined largely by physical and chemical properties related to chemical size and general structure (e.g., lipophilicity, vapor pressure, etc.), it is reasonable to assume that perylene will be absorbed and distributed similarly to other PAHs of similar size and structure with similar physical and chemical properties (e.g., BaP). PAHs, in general, are metabolized in multiple tissues in the body into more soluble metabolites, including dihydrodiols, phenols, quinones, and epoxides, that form conjugates with glucuronide, glutathione (GSH), or sulfate (U.S. EPA, 2017b; IARC, 2010; ATSDR, 1995).

Several studies have evaluated the potential for perylene to induce metabolic enzymes. Most studies have focused on aryl hydrocarbon hydroxylase (AHH), an enzyme induced by many PAHs (Neubert and Tapken, 1988; Asokan et al., 1986; Mukhtar et al., 1982; Neubert and Tapken, 1978). Findings for AHH induction by perylene are mixed. In dermal studies with neonatal rats, Asokan et al. (1986) reported a significant 1.6-fold induction of AHH in neonatal rat skin, but not neonatal liver, while Mukhtar et al. (1982) observed the opposite (a significant 1.6-fold increase in AHH in neonatal liver, but not the skin). In both studies, the induction by perylene was approximately an order of magnitude lower than known inducers (e.g., 3-methyl-cholanthrene, 7,12-demethylbenzanthracene). During gestational exposures, both AHH activity and overall “BaP hydrolase” activity were elevated in maternal livers, but not in fetal livers (Neubert and Tapken, 1988, 1978). “BaP hydrolase” activity was measured as total BaP breakdown, as opposed to activities of specific hydrolase enzymes. In these studies, the magnitude of perylene enzyme induction was ∼25% lower than induction by BaP. In male rats, i.p. injections of perylene did not induce AHH in the liver (Harris et al., 1988). In vitro, perylene is a weak inducer of AHH and a weak binder of aryl hydrocarbon receptors (AhRs) in rat hepatocytes (Piskorska-Pliszczynska et al., 1986).

In general, exposure to perylene did not lead to induction of other metabolic enzymes measured in skin and/or liver, including 7-ethoxyresorufin O-deethylase (EROD), 7-ethoxycoumarin O-deethylase (ECOD), benzphetamine n-demethylase (BPD), nicotinamide adenine dinucleotide phosphate (NADPH)-cytochrome c, nicotinamide adenine dinucleotide hydrogen (NADH)-ferricyanide reductase, or cytochrome P450 (CYP450) (Harris et al., 1988; Asokan et al., 1986; Mukhtar et al., 1982). Following i.p. exposure to perylene, there was no evidence of induction of glycolytic enzymes, pyruvate kinase, or lactate dehydrogenase in the mouse lung (Rády et al., 1981; Rády et al., 1980).