# 1 INTRODUCTION

Perylene, CASRN 198-55-0, is a polycyclic aromatic hydrocarbon (PAH) compound that occurs in coal tar and fossil fuels and is found as a byproduct of incomplete combustion (NLM, 2022c). Its structure consists of five fused aromatic rings and can be described as a dinaphthalene. Perylene is preregistered with Europe’s Registration, Evaluation, Authorisation, and Restriction of Chemicals (REACH) program (ECHA, 2022) and is listed on the U.S. EPA’s Toxic Substances Control Act (TSCA) public inventory (NLM, 2022c; U.S. EPA, 2021).

Perylene is used as a fluorescent lipid probe in membrane cytochemistry and in the production of organic semiconductors (NLM, 2022c). Perylene is not produced commercially in the United Sates; it can be produced by the condensation of naphthalene in the presence of mixed Lewis acid and protic acid catalysts or by reaction of phenanthrene with acrolein in anhydrous hydrofluoric acid (NLM, 2022c).

The empirical formula for perylene is C_20_H_12_; its structure is shown in Figure 1. Table 1 provides physicochemical properties for perylene. Perylene is a yellow to colorless crystalline solid. Its negligible water solubility and negligible vapor pressure indicate that this substance is hydrophobic and nonvolatile and will exist predominantly in the particulate phase in air. Additionally, volatilization from water surfaces or moist soil surfaces is expected to be low based upon the predicted Henry’s law constant of 1.06 × 10^−6^ atm-m^3^/mole. In the atmosphere, perylene has an estimated half-life of 3.7 hours, calculated from a predicted rate constant of 3.45 × 10^−11^ cm^3^/molecule-second at 25°C for reaction with photochemically-produced hydroxyl radicals (U.S. EPA, 2012). The estimated soil adsorption coefficient (K_oc_) for perylene indicates minimal potential for mobility in soil; therefore, perylene has low potential for migration into groundwater (U.S. EPA, 2012). Perylene is not expected to undergo hydrolysis due to its lack of hydrolysable functional groups.

Figure 1 Perylene (CASRN 198-55-0) Structure

Perylene (CASRN 198-55-0) Chemical Structure polycyclic aromatic hydrocarbon

Table 1 Physicochemical Properties of Perylene (CASRN 198-55-0)

Property (unit) | Value^a^
Molecular weight (g/mol) | 252.32
Physical state | Solid
Boiling point (°C) | >350 (estimated, range 443–487); 350–400 (sublimes)^b,c^
Melting point (°C) | 274
Density (g/cm^3^ at 25°C) | 1.28 (predicted average)
Vapor pressure (mm Hg at 25°C) | 5.25 × 10^−9^
pH (unitless) | NA
pKa (unitless) | NA
Solubility in water (mg/L at 25°C) | 4.0 × 10^−4^ (reported as 1.58 × 10^−9^ mol/L)
Octanol-water partition coefficient (log K_ow_) | 6.04
Henry’s law constant (atm-m^3^/mol at 20°C) | 1.06 × 10^−6^ (predicted average)
Soil adsorption coefficient (K_oc_) (L/kg) | 4.07 × 10^5^ (predicted average)
Atmospheric OH rate constant (cm^3^/molecule-sec at 25°C) | 3.45 × 10^−11^ (predicted average)
Atmospheric half-life (d) | 0.31 d (3.7 h)^d^
Relative vapor density (air = 1) | NA
Flash point (open cup in °C) | 230 (predicted average)

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard (perylene; CASRN 198-55-0) (U.S. EPA, 2022c). Accessed on January 18. 2023. All values are experimental averages unless otherwise specified.

b NLM (2022c).

c NIST (2022): Goldfarb and Suuberg (2008).

d Calculated half-life in troposphere; t_1/2_ = 0.693/k_OH_ [OH] where k_OH_ = 3.45 × 10^−11^ and [OH] = 1.5 × 10^6^ molecules/cm^3^.

NA = not applicable; U.S. EPA = U.S. Environmental Protection Agency.

A summary of available toxicity values for perylene from the U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Toxicity Values for Perylene (CASRN 198-55-0)

Source/Parameter^a,b^ | Value (applicability) | Notes | Reference
Noncancer
IRIS | NV | NA | U.S. EPA (2022e)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
ATSDR | NV | NA | ATSDR (2021); ATSDR (1995)
IPCS | NV | NA | IPCS (2020)
CalEPA | NV | NA | CalEPA (2022); CalEPA (2020)
OSHA | NV | NA | OSHA (2021a); OSHA (2021b); OSHA (2021c)
NIOSH | NV | NA | NIOSH (2018)
ACGIH | NV | NA | ACGIH (2021)
TCEQ (RfD) | 0.02 mg/kg-d | Basis for RfD not specified; value developed with TECQ’s protocol (TCEQ, 2015). | TCEQ (2022)
Cancer
IRIS | NV | NA | U.S. EPA (2022e)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
NTP | NV | NA | NTP (2021)
IARC (WOE) | Group 3, not classifiable as to its carcinogenicity to humans | Inadequate data to permit an evaluation of the carcinogenicity of perylene in experimental animals | IARC (2010)
CalEPA | NV | NA | CalEPA (2022); CalEPA (2020)
ACGIH | NV | NA | ACGIH (2021)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; TCEQ = Texas Commission of Environmental Quality.

b Parameters: RfD = reference dose; WOE = weight of evidence.

NA = not applicable; NV = not available.

Literature searches were conducted in June 2019 and updated in January 2023 for studies relevant to the derivation of provisional toxicity values for perylene, CASRN 198-55-0. Searches were conducted using the U.S. EPA’s Health and Environmental Research Online (HERO (https://wamssoprd.epa.gov/oam/server/obrareq.cgi?encquery%3DdOP6QPpZQGyH7si23dIs8VBHaG6h9tp%2B4xleHfTc8LE1Bpy0AV9nN%2BHGzZ09uk3IlvSC9eUQcPh5TgNLuDY7wC3uLAWLzDh8F1ntW4YhoWP3TGzfL6yXhoEw6SjKHjC3QGWAjQrl5ecn7W7f6Bzm9b%2FWNgnXxWucbZZMUXYGiR4RegDFAnEccvocXe9gFmpeQGfcT%2BJ8TMOFbKa9otExbFZoWJDaQ5KFqibarnKqomLYHih0105siUrUNRITsU4kJ52dkqRNFJ1agsyASnGEyvfundbeiecCf6IJCBdONFZn5bDKlUOOUjh6S8ZN0EeFeKLfh2p2LIXq11OCb5pISeq1ogAYN3a50kv08H36pDzMN5N0uSOBtJ4w0rycXWqmeWVEK03C9XU4BUVHr%2BdfeOO3D4oQM53CSXLJU6L0XLo%3D%20agentid%3DWebgateEPADomain%20ver%3D1%20crmethod%3D2%26cksum%3D452f484d328e40c6ff79d3f21948000c2a9af457)) database of scientific literature. HERO searches the following databases: PubMed, Web of Science, TOXLINE^1^ (including TSCATS1), and Web of Science. The National Technical Reports Library (NTRL) was searched for government reports from 2018 through September 2020. The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), the U.S. EPA Chemical Data Access Tool (CDAT), the U.S. EPA ChemView, the U.S. EPA Integrated Risk Information System (IRIS), the U.S. EPA Health Effects Assessment Summary Tables (HEAST), the U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), the U.S. EPA TSCATS2/TSCATS8e, the U.S. EPA High Production Volume (HPV), Chemicals via International Programme on Chemical Safety (IPCS) INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Co-operation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

Following the literature search, literature was screened and categorized using systematic review methods to identify studies pertinent to understanding the potential human health hazard of perylene. The resulting relevant literature was developed into a systematic evidence map (SEM) using the methods outlined in Thayer et al. (2022). A description of how the SEM was used during assessment development can be found in Appendix A.

1 Note that this version of TOXLINE is no longer updated (https://www.nlm.nih.gov/databases/download/toxlinesubset.html); therefore, it was not included in the literature search update from January 2023.