# QUESTIONS REGARDING PPRTVS

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) CPHEA website at https://ecomments.epa.gov/pprtv.