# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Daniel D. Petersen, MS, PhD, DABT, ATS, ERT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## CONTRIBUTOR

- Jeffrey Swartout, MS
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Elizabeth Owens, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Q. Jay Zhao, PhD, MPH, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## ADDITIONAL INTERNAL REVIEWERS

- John C. Lipscomb, PhD, DABT, Fellow ATS
  Center for Environmental Solutions and Emergency Response, Cincinnati, OH
- Jeffrey Swartout, MS
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## PRIMARY EXTERNAL REVIEW

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.