# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF ORAL REFERENCE DOSES

### 3.1.1 Derivation of a Subchronic Provisional Reference Dose

The database of potentially relevant studies for deriving a subchronic provisional reference dose (p-RfD) for PETN includes numerous clinical studies evaluating the compound’s therapeutic use as a venous dilator at doses ranging from 0.57−4.6 mg/kg-day for the long-term treatment of cardiovascular diseases (see Table 3A). In addition, several acute studies have established a single-exposure effective dose for reduced blood pressure as low as 0.29 mg/kg (Dagenais et al., 1969). The available animal studies are considered less relevant for deriving the subchronic p-RfD due to the extent of the human database and the much higher doses (39.1−3,120 mg/kg-day) evaluated in animal studies, including a subchronic-duration dietary study in mice and rats (Bucher et al., 1990; NTP, 1989) and a reproductive/developmental (R/D) gavage study in rats (Quinn et al., 2009). Effects associated with the therapeutic use of organic nitrates are well characterized and generally secondary to actions on the cardiovascular system, including hypotension, headache, and dizziness due to cerebral vasodilation, along with other subjective complaints [reviewed by Daiber et al. (2008); Bode-Böger and Kojda (2005); Murad (1990)]. As discussed in the “Human Studies” section and shown in Table 3A, several of the available clinical trials reported an increase in toxicologically relevant side effects following exposure to PETN.

The designation of the POD for the subchronic p-RfD for PETN is focused on identifying the lowest therapeutic dose because the primary effect of vasodilation is considered to be toxicologically relevant in the general population, particularly in chronically exposed individuals with pre-existing hypotension or susceptible to hypotension; such people include pregnant women, infants, the elderly suffering from dehydration or malnutrition, diabetics, and those taking certain medications (diuretics, antidepressants, erectile dysfunction drugs). The lowest dose of PETN associated with a vasodilatory effect in the continuous-exposure clinical trials is 0.57 mg/kg-day in the Phillips (1953) study. This study, however, involved intermittent concurrent treatment with NTG, which elicits the same effects as PETN, thereby making the determination of the specific effective dose of PETN difficult. Because PETN and NTG act in the same way, though NTG has a shorter half-life, the combined therapeutically effective dose will be higher than for either drug alone. This study, and several others with concurrent NTG treatment (Cass and Cohen, 1961; Plotz, 1960; Rosenberg and Michelson, 1955) were not considered further as the basis for the POD. Of the remaining PETN-only, continuous-exposure studies, the lowest effective vasodilatory dose of PETN was 0.86 mg/kg-day (Hedges and Gordon, 1965). Note that the most of the studies mentioned above with concurrent NTG treatment (Cass and Cohen, 1961; Plotz, 1960; Rosenberg and Michelson, 1955) also showed the same lowest effective dose at 0.86 mg/kg-day. In those studies, NTG treatment was episodic, and thus may not have consistently influenced the effective dose of PETN. Those studies are thus supportive of using the 0.86 mg/kg-day LOAEL as a potential POD. Vasodilation was implicit in Hedges and Gordon (1965), and in most of the other clinical trials, and was judged to be present based on the observed therapeutic efficacy at the treatment dose. Other clinical studies reported effective continuous treatment results at doses ranging from 50 mg (Bohm and Haustein, 1998) to 80 mg (Edson et al., 1961) and higher (Schleussner et al., 2014; Schnorbus et al., 2010; Jurt et al., 2001; Shrivastava et al., 1983; Aubert et al., 1970). The effective therapeutic dose for all these studies was the lowest (or only) administered treatment level. No clear NOAELs for therapeutic efficacy were reported in the continuous-exposure studies. Rosenberg and Michelson (1955) briefly mentioned a lack of therapeutic efficacy at a dose of 0.86 mg/kg-day for five patients in a preliminary trial to their main study. This study, however, was discounted because the study was confounded by concurrent treatment with NTG.

NOAELs for side effects in the continuous-exposure clinical studies have been established in placebo-controlled studies, without concurrent NTG treatment, at doses as low as 0.86 mg/kg-day in the relevant (not confounded by NTG treatment) continuous exposure studies for headaches in 3/72 patients (Hedges and Gordon, 1965). Evidence from the placebo-controlled studies of greater than 4 weeks showed NOAELs for side effects ranging from 0.57−2.3 mg/kg-day (Hedges and Gordon, 1965; Plotz, 1960; Rosenberg and Michelson, 1955; Phillips, 1953).

Several acute-exposure (single-dose) studies reported effective doses of PETN; these doses ranged from 0.29−1.1 mg/kg (Dragoni et al., 2007; Bohm and Haustein, 1998; Giles et al., 1981; Amsterdam et al., 1980; Shellock et al., 1980; Dagenais et al., 1969). The lowest effective dose from a single exposure (0.29 mg/kg) was reported by Dagenais et al. (1969) to be associated with a 5−10% reduction in systolic blood pressure in 15 angina patients; this result by itself, would seem to define the most sensitive effect, which, in this case, was an overt reduction in blood pressure, rather than vasodilation.

#### Conclusion

Environmental exposures to PETN, as outlined previously, could lead to toxicologically relevant vasodilatory effects in the general healthy population, but particularly in chronically exposed individuals with pre-existing hypotension or those susceptible to hypotension, such as pregnant women, infants, the elderly suffering from dehydration or malnutrition, those with diabetes, and those taking certain medications (diuretics, antidepressants, erectile dysfunction drugs). Thus, the level of potential concern for the general population would be the lowest effective therapeutic dose.

#### Approach for Deriving the Subchronic p-RfD

The lowest LOAEL applicable to continuous exposure of PETN is (0.86 mg/kg-day) from the continuous-exposure clinical study of Hedges and Gordon (1965). Some single-dose studies had lower effect levels between 0.29−0.71 mg/kg (Bohm and Haustein, 1998; Giles et al., 1981; Amsterdam et al., 1980; Dagenais et al., 1969). However, given the uncertainties in extrapolating an acute exposure to an equivalent continuous exposure, effect levels derived from the repeat-exposure clinical studies are judged to be much more representative of continuous daily human exposures. Therefore, the single-dose acute studies are not considered further as the basis for the subchronic p-RfD.

A LOAEL of 0.86 mg/kg-day is selected as the POD for deriving the subchronic p-RfD based on implicit vasodilation, given the therapeutic efficacy of PETN at that average daily dose (ADD) administered to coronary heart disease patients (Hedges and Gordon, 1965). Angina was reduced by more than two-thirds by patients taking PETN compared with control. Some patients also left the study because of side effects of lowered blood pressure, again indicating therapeutic efficacy. The ADD was estimated from the treatment schedule of one 30-mg extended-release tablet every 12 hours, assuming a 70 kg adult body weight. The 0.86-mg/kg-day dose level was the lowest treatment dose; a NOAEL was not established in this study. Although the treatment protocol included a 2-week placebo administration phase intervening between the two 2-week PETN treatment phases, averaging the effective PETN dose over the entire 6 weeks was judged to be inappropriate. The latter decision is based on the reported efficacy of treatment during the first 2 weeks of PETN administration (Hedges and Gordon, 1965) and immediate biological action reported following single doses of 20−40 mg PETN (Amsterdam et al., 1980; Dagenais et al., 1969). These observations are consistent with the short half-life and duration of efficacy for PETN, both on the order of a few hours (Weber et al., 1995). In addition, the LOAEL of 0.86 mg/kg-day may be near a threshold, given the observations of no effect of PETN in a preliminary study (Rosenberg and Michelson, 1955), but with effects at the same dose in additional placebo-controlled continuous studies 4 weeks in duration or longer (Cass and Cohen, 1961; Plotz, 1960; Roberts, 1958). Thus, there is evidence across the database that NOAELs and LOAELs are overlapping. All these considerations indicate that the biological activity of PETN depends more on the immediate (peak) internal concentration than on a longer-term average.

Therefore, although the LOAEL POD is based on a relatively short exposure duration, the effects are expected to be due to the acute vasodilatory effects of PETN, and longer-term exposure would not be required to evaluate efficacy. In those studies that used the extended-release formulation, the internal exposure would be somewhat continuous. As for the potential for increased toxicity with longer exposures, few side effects were evident at exposures up to 30 weeks. The side effects were generally mild, consisting of headaches, dizziness, and nausea, all attributable to the primary effect of vasodilation. Furthermore, significantly higher doses in subchronic-duration animal studies reveal no toxicologically relevant effects with a LOAEL of 200 mg/kg-day in rats, and a NOAEL of 3,120 mg/kg-day in mice (Bucher et al., 1990; NTP, 1989). Therefore, the lowest effective therapeutic dose in evidence from the large clinical study database is deemed appropriate as the basis for a LOAEL in the general human population and to serve as a POD for the subchronic p-RfD. The subchronic p-RfD for PETN, based on the LOAEL of 0.86 mg/kg-day (Hedges and Gordon, 1965), is supported by two additional studies (Cass and Cohen, 1961; Plotz, 1960); however, these two studies were partially confounded by concurrent treatment with NTG. Thus, the subchronic p-RfD is derived as follows:

Subchronic p-RfD = LOAEL ÷ UF_C_ = 0.86 mg / kg-day ÷ 100 = 9 × 10^− 3^ mg / kg-day

Table 6 summarizes the uncertainty factors for the subchronic p-RfD for PETN.

Table 6 Uncertainty Factors for the Subchronic p-RfD for PETN

UF | Value | Justification
UF_A_ | 1 | A UF_A_ of 1 is applied because the assessment is based on clinical data from humans.
UF_D_ | 3 | A UF_D_ of 3 (10^0.5^) is applied. The database contains numerous clinical oral studies, including several recent, medium to large, well-designed, placebo-controlled, double-blind, randomized studies of 4−30 wk in duration, that identify NOAELs or LOAELs in cardiovascular disease patients treated with PETN to induce coronary vasodilation at doses up to 4.6 mg/kg-d. The database also includes effects or only mild nonspecific effects on body weight at high doses (≥200 mg/kg-d) (Bucher et al., 1990; NTP, 1989), as well as an oral R/D toxicity screening study in rats that found no effects at doses up to 1,000 mg/kg-d (Quinn et al., 2009). However, a multigeneration reproductive toxicity study or a developmental teratology study have not been conducted.
UF_H_ | 10 | A UF_H_ of 10 is applied for intraspecies variability to account for human-to-human variability in susceptibility (including hypotensive individuals) in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of PETN in humans.
UF_L_ | 3 | A UF_L_ of 3 (10^0.5^) is applied because of overlapping NOAEL and LOAEL values likely near the threshold response, for example, Rosenberg and Michelson (1955).
UF_S_ | 1 | UF_S_ is not applicable to the subchronic p-RfD because the principal study was 8 wk in duration and because the very short half-life of NO causes dosing to be episodic, not cumulative, and thus the effects would not be dependent on duration.
UF_C_ | 100 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

LOAEL = lowest-observed-adverse-effect level; NO = nitric oxide; NOAEL = no-observed-adverse-effect level; PETN = pentaerythritol tetranitrate; p-RfD = provisional reference dose; R/D = reproductive/developmental; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies variability uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Confidence in the subchronic p-RfD for PETN is medium as explained in Table 7.

Table 7 Confidence Descriptors for the Subchronic p-RfD for PETN

Confidence Categories | Designation | Discussion
Confidence in principal study | M | Confidence in the principal study (Hedges and Gordon, 1965) is medium. The study appears to be of high quality, with a single-blind randomized crossover design, 72 subjects, and clear, well-reported results. However, a NOAEL was not identified because effects were seen at both doses in the study.
Confidence in database | M | Confidence in the database is medium. The database comprises multiple well-conducted and well-reported clinical trials that demonstrate the effects of PETN in cardiac patients and healthy volunteers at exposure levels near the POD. The database also contains short-term-, subchronic-, and chronic-duration oral studies in rats and mice that found either no effects or only mild nonspecific effects on body weight at high doses (≥200 mg/kg-d) (Bucher et al., 1990; NTP, 1989), as well as an oral R/D toxicity screening study in rats that found no effects at doses up to 1,000 mg/kg-d (Quinn et al., 2009). However, neither a multigenerational reproductive study nor a developmental teratology study has been done.
Confidence in subchronic p-RfD^a^ | M | Overall confidence in the subchronic p-RfD is medium.

a The overall confidence cannot be greater than lowest entry in table (medium).

M = medium; NOAEL = no-observed-adverse-effect level; PETN = pentaerythritol tetranitrate; POD = point of departure; p-RfD = provisional reference dose; R/D = reproductive/developmental.

### 3.1.2 Derivation of a Chronic Provisional Reference Dose

As discussed for the derivation of the subchronic p-RfD, the database of potentially relevant studies for deriving a chronic reference dose value for PETN includes numerous clinical studies evaluating the compound’s therapeutic use as a venous dilator for the long-term treatment of cardiovascular diseases using therapeutic doses ranging from 0.57−4.6 mg/kg-day (see Table 3A). Due to the extent of the human database, the available animal studies evaluating much higher doses (39.1−3,120 mg/kg-day), including a chronic-duration dietary study in mice and rats (Bucher et al., 1990; NTP, 1989) and an R/D gavage study in rats (Quinn et al., 2009), were not considered as principal studies for deriving the chronic p-RfD. While no chronic-duration clinical studies were identified, any potential toxicologically relevant effects of PETN are expected to be due to acute vasodilatory effects of PETN and transient in nature. Further, the results of the chronic-duration animal studies revealed no additional noncancer hazards. Therefore, short-term-duration clinical studies are considered appropriate for deriving the chronic p-RfD.

#### Approach for Deriving the Chronic p-RfD

The basis for the chronic p-RfD is the same as for the subchronic p-RfD, with the lowest effective therapeutic dose serving as a LOAEL and vasodilation as the critical effect. The LOAEL is 0.86 mg/kg-day for vasodilation, with potential for reduced blood pressure, established in the clinical study of Hedges and Gordon (1965). The chronic p-RfD for PETN is derived as follows:

Chronic p-RfD = NOAEL ÷ UF_C_ = 0.86 mg / kg-day ÷ 100 = 9 × 10^− 3^ mg / kg-day

Table 8 summarizes the uncertainty factors for the chronic p-RfD for PETN.

Table 8 Uncertainty Factors for the Chronic p-RfD for PETN

UF | Value | Justification
UF_A_ | 1 | A UF_A_ of 1 is applied because the assessment is based on clinical data from humans.
UF_D_ | 3 | A UF_D_ of 3 (10^0.5^) is applied. The database contains numerous clinical oral studies, including several recent, medium to large, well-designed, placebo-controlled, double-blind, randomized studies of 4−30 wk in duration that identify NOAELs or LOAELs in cardiovascular disease patients treated with PETN to induce coronary vasodilation at doses up to 4.6 mg/kg-d. The database also includes short-term-, subchronic-, and chronic-duration oral studies in rats and mice that found either no ild nonspecific effects on body weight at high doses (≥200 mg/kg-d) (Bucher et al., 1990; NTP, 1989), as well as an oral R/D toxicity screening study in rats that found no effects at doses up to 1,000 mg/kg-d (Quinn et al., 2009). However, a multigeneration reproductive toxicity study or a developmental teratology study have not been conducted.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human-to-human variability in susceptibility (including hypotensive individuals) in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of PETN in humans.
UF_L_ | 3 | A UF_L_ of 3 (10^0.5^) is applied because of overlapping NOEAL and LOAEL values likely near the threshold of response. For example, Rosenberg and Michelson (1955).
UF_S_ | 1 | A UFS of 1 is applied. Although the assessment is based on relatively short 8−30-wk clinical trials in humans, any potential toxicologically relevant effects of PETN are expected to be due to the acute vasodilatory effects of PETN and transient in nature. Furthermore, the database included 2-yr studies in rats and mice that assessed systemic toxicity at doses much higher than the human clinical doses and reported no effects. Therefore, increased risk is not expected following longer duration exposure.
UF_C_ | 100 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PETN = pentaerythritol tetranitrate; p-RfD = provisional reference dose; R/D = reproductive/developmental; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies variability uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

The confidence of the chronic p-RfD for PETN is medium as explained in Table 9.

Table 9 Confidence Descriptors for the Chronic p-RfD for PETN

Confidence Categories | Designation | Discussion
Confidence in the principal study | M | Confidence in the principal study (Hedges and Gordon, 1965) is medium. The study appears to be of high quality, with a single-blind randomized crossover design, 72 subjects, and clear, well-reported results. However, a NOAEL was not identified, because effects were observed at both doses used in the study.
Confidence in database | M | Confidence in the database is medium. The database comprises multiple well-conducted and well-reported clinical trials that demonstrate the effects of PETN in cardiac patients and healthy volunteers at exposure levels near the POD. The database also contains short-term-, subchronic-, and chronic-duration oral studies in rats and mice that found either no effects or only mild nonspecific effects on body weight at high doses (≥200 mg/kg-d) (Bucher et al., 1990; NTP, 1989), as well as an oral R/D toxicity screening study in rats that found no effects at doses up to 1,000 mg/kg-d (Quinn et al., 2009). However, neither a multigenerational reproductive study nor a developmental teratology study has been done.
Confidence in chronic p-RfD^a^ | M | Overall confidence in the subchronic p-RfD is medium.

a The overall confidence cannot be greater than lowest entry in table (medium).

M = medium; NOAEL = no-observed-adverse-effect level; PETN = pentaerythritol tetranitrate; POD = point of departure; p-RfD = provisional reference dose; R/D = reproductive/developmental.

## 3.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

No information was available on the subchronic or chronic inhalation toxicity of PETN, thus precluding the derivation of provisional reference concentration (p-RfC) values for PETN.

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

A summary of the noncancer provisional reference values is shown in Table 10.

Table 10 Summary of Noncancer Reference Values for PETN (CASRN 78-11-5)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED) | UF_C_ | Principal Study
Subchronic p-RfD (mg/kg-d) | Human/both | Vasodilation | 9 × 10^−3^ | LOAEL | 0.86 | 100 | Hedges and Gordon (1965) ^a^
Chronic p-RfD (mg/kg-d) | Human/both | Vasodilation | 9 × 10^−3^ | LOAEL | 0.86 | 100 | Hedges and Gordon (1965) ^a^
Subchronic p-RfC (mg/m^3^) | NDr
Chronic p-RfC (mg/m^3^) | NDr

a See Table 3A.

HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NDr = not determined; PETN = pentaerythritol tetranitrate; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

The cancer weight-of-evidence (WOE) descriptor for PETN is “Suggestive Evidence of Carcinogenic Potential” following oral exposure and “Inadequate Information to Assess Carcinogenic Potential” following inhalation exposure; see the details below and in Table 11.

Table 11 Cancer WOE Descriptors for PETN

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | No human data are available.
“Likely to Be Carcinogenic to Humans” | NS | NA | The available data do not support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | Selected | Oral | There is suggestive evidence of Zymbal gland tumors in M and F rats and thyroid tumors in F rats in a 2-yr oral bioassay (Bucher et al., 1990; NTP, 1989). There is no evidence of carcinogenicity in M or F mice in a 2-yr oral bioassay (Bucher et al., 1990; NTP, 1989)(see Appendix A).
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Inhalation | No carcinogenicity studies are available that evaluated inhalation exposure.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | The available data do not support this descriptor.

F = female(s); M = male(s); NA = not applicable; NS = not selected; PETN = pentaerythritol tetranitrate; WOE = weight of evidence.

Following U.S. EPA (2005) Guidelines for Carcinogen Risk Assessment, the database for exposure to PETN provides evidence leading to a WOE descriptor of “Suggestive Evidence of Carcinogenic Potential” following oral exposure, in that both rare (normal incidence 1% or less) Zymbal gland and thyroid gland tumors were identified. In a 2-year bioassay in rats, incidences of rare Zymbal gland carcinomas or adenomas were observed in all treated groups of both sexes (see Table B-5). The incidences did not reach statistical significance (p < 0.05) when compared with control group incidences. However, they are rare tumors (both concurrent control and historical control incidence is less than 1%) that did exceed mean historical incidences for each sex, and there was a statistically significant trend in females (p < 0.028) (see Table B-5). Site concordance between males and females and a dose-response in females also adds to the WOE. Considering the overall occurrence of rare Zymbal gland tumors in 3 of 35 (9%) of dosed female rats compared with none in the controls in the chronic study, and a Zymbal gland tumor in one high-dose female rat in the subchronic-duration 14-week study, NTP (1989) concluded that the Zymbal gland tumors were possibly related to PETN exposure. Additional neoplastic findings in the rats included thyroid gland follicular cell adenomas or carcinomas in a small number of high-dose females (see Table B-5). The high-dose incidence was not statistically significantly higher than that in controls, but the incidence exceeded historical control incidences and showed a statistically significant dose-related trend (Cochran-Armitage trend test, p = 0.016; see Table B-5). For the purposes of this PPRTV assessment, the U.S. EPA considers these thyroid tumors to be treatment related. Because there were no indications of increased thyroid follicular cell adenomas, carcinomas, or hyperplasia in chronically exposed males, the small increase in follicular cell tumors in females was not considered PETN-related by NTP; however, based on the increase in neoplasms of the Zymbal gland, the NTP study authors concluded that this study provided “Equivocal Evidence of Carcinogenic Activity” of PETN for male and female F344/N rats.

In this assessment, the study results show a rare tumor type (Zymbal gland tumors) with a statistically significant dose-response in females, but not males (Bucher et al., 1990; NTP, 1989). This tumor type also appears in a high-dose female in the subchronic (14-week) assay. There is also evidence of thyroid tumors, with a statistically significant trend in females. NTP designated the carcinogenic potential “Equivocal.” U.S. EPA finds that the observation of rare Zymbal gland tumors in both female and male rats and thyroid tumors in female rats constitute sufficient evidence for the identification of a hazard, but not strong enough to warrant a descriptor of “Likely to Be Carcinogenic to Humans.” Thus, for this assessment, the cancer descriptor for PETN is determined to be “Suggestive Evidence of Carcinogenic Potential.”

## 3.5 MODE-OF-ACTION DISCUSSION

The Guidelines for Carcinogenic Risk Assessment (U.S. EPA, 2005) defines mode of action (MOA) “…as a sequence of key events and processes, starting with interaction of an agent with a cell, proceeding through operational and anatomical changes, and resulting in cancer formation.” Examples of possible modes of carcinogenic action for any given chemical include “mutagenicity, mitogenesis, programmed cell death, cytotoxicity with reparative cell proliferation, and immune suppression.”

A limited amount of information is available on the genotoxicity and mutagenicity of PETN. Available in vitro data indicate that PETN and its metabolites are not mutagenic in bacterial systems (NTP, 1989; Mortelmans et al., 1986; Whong et al., 1980). Limited in vitro data indicate that PETN has the potential to induce clastogenic effects in mammalian cells (NTP, 1989). No additional data regarding potential mechanisms of carcinogenicity are available. Thus, a detailed MOA discussion for PETN is precluded.

## 3.6 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

### 3.6.1 Derivation of a Provisional Oral Slope Factor

Although there is sufficient data to derive a provisional oral slope factor (p-OSF), the U.S. EPA cancer guidelines (U.S. EPA, 2005) state that a quantitative assessment is not usually conducted when the cancer descriptor is “Suggestive Evidence of Carcinogenic Potential.” However, they go on to say that, if a quantitative assessment is useful for a specific purpose, it may be conducted. Therefore, for purposes of this provisional value assessment, a screening p-OSF is presented in Appendix A.

### 3.6.2 Derivation of a Provisional Inhalation Unit Risk

The lack of data on the carcinogenicity of PETN following inhalation exposure precludes deriving a quantitatively estimated provisional inhalation unit risk (p-IUR).

### 3.6.3 Summary of Cancer Risk Estimates

A summary of the cancer risk estimates is shown in Table 12.

Table 12 Summary of Cancer Risk Estimates for PETN (CASRN 78-11-5)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
Screening p-OSF (mg/kg-d)^−1^ | F344/N rat, F | Combined Zymbal gland and thyroid (see Appendix A) | 4.3 × 10^−3^ | Bucher et al. (1990); NTP (1989)
p-IUR (mg/m^3^)^−1^ | NDr

F = female(s); NDr = not determined; PETN = pentaerythritol tetranitrate; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.