# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

Tables 3A and 3B provide overviews of the relevant noncancer and cancer evidence bases, respectively, for PETN and include all potentially relevant acute and repeated-dose short-term, subchronic, and chronic studies as well as reproductive and developmental toxicity studies. Principal studies used in the PPRTV assessment for derivation of provisional toxicity values are identified in bold. The phrase “statistical significance” and the term “significant,” used throughout the document, indicate a p-value of < 0.05 unless otherwise specified. Single-dose studies are not time averaged over 24 hours, as the effects of PETN are related more to peak exposure levels than longer-term averages as the half-life is much less than 24 hours. Thus single-dose study dosimetry is expressed as mg/kg rather than mg/kg-day.

Table 3A Summary of Potentially Relevant Noncancer Data for PETN (CASRN 78-11-5)

Category^a^ | Number of Male/Female, Strain, Species, Study Type, Study Duration, Reported Doses | Adjusted Dosimetry^b^ | Critical Effects | NOAEL^b^ | LOAEL^b^ | Reference (comments) | Notes^c^
Human
1. Oral (mg/kg-d)
Acute | 37 healthy adult male volunteers (10 placebo, 9 PETN, 18 other nitrates). Single dose 80-mg tablet. | Once; 0, 1.1 mg/kg | 5.7% decrease in systolic blood pressure; no toxicologically relevant side effects reported. | NDr | 1.1 | Dragoni et al. (2007); (Double-blind clinical trial with random allocation.) | PR
Acute | 10 M, 2 F (12 total) heart failure patients: 8 of the subjects received both placebo and PETN treatment, 4 PETN only. Time between treatment administration was determined by “return-to-baseline” hemodynamics. Single dose 40-mg tablet. | Once; 0, 0.57 mg/kg | 7−14% decrease in systemic arterial pressure 20−240 min after administration; no toxicologically relevant side effects reported. | NDr | 0.57 | Amsterdam et al. (1980); (Double-blind clinical trial, crossover design [pre- and post-treatment comparison].) | PR
Acute | 14 M, 5 F (19 total) heart failure patients. Single dose 80-mg tablet. | Once; 1.1 mg/kg | 8−10% decrease in systemic arterial pressure 1−5 h after administration, compared with pretreatment values; no toxicologically relevant side effects reported. | NDr | 1.1 | Shah et al. (1980); Shellock et al. (1980); (Clinical trial [pre- and post-treatment comparison].) | PR
Acute | 15 M angina patients: all patients received each treatment at random over a 5-d period (1 treatment/d, 2 treatment d, 3 placebo d). Single dose 20-, 40-mg tablets. | Once; 0, 0.29, 0.57 mg/kg | 5−10% decrease in systolic blood pressure in supine or standing position 90 min after low- or high-dose administration, compared with the placebo; no toxicologically relevant side effects reported. | NDr | 0.29 | Dagenais et al. (1969); (Double-blind clinical trial, crossover design.) | PR
Acute | 10 M angina patients: each subject received both placebo and PETN treatment; 7-d interval between different treatments. Single dose 40-mg tablet. | Once; 0, 0.57 mg/kg | Increased time to exercise-induced angina (implicit vasodilation); no effect on blood pressure; the study authors did not report whether any toxicologically relevant side effects occurred during the trial. | NDr | 0.57 | Giles et al. (1981); (Double-blind clinical trial [pre- and post-treatment comparison].) | PR
Acute | 10 M healthy adult volunteers: each subject received both placebo and PETN treatment; 7-d interval between different treatments. Single dose 2 × 80-mg tablets. | Once; 0, 2.3 mg/kg | Suppression of serum cGMP increase (vasodilation precursor); blood pressure reduced; the study authors did not report whether any toxicologically relevant side effects occurred during the trial. | NDr | 2.3 | Henstridge et al. (2009); (Double-blind clinical trial [pre- and post-treatment comparison].) | PR
Acute | 6 M, 6 F (12 total) healthy adult volunteers: all patients received each treatment at random; 7-d interval between different treatments. Single dose 25-, 50-, or 80-mg tablets. | Once; 0, 0.36, 0.71, 1.1 mg/kg | Implicit vasodilation (reduction in plasma viscosity and capillary erythrocyte velocity); 7% reduction in blood pressure at 1.1 mg/kg-d; the study authors did not report whether any toxicologically relevant side effects occurred during the trial. | 0.36 | 0.71 | Bohm and Haustein (1998); (Single-blind clinical trial, crossover design [pre- and post-treatment comparison].) | PR
Short term | 5 M healthy and 5 M coronary artery disease patients per group; 3 d. Short-term dose 2 × 150-mg tablets/d. | 0, 4.3 mg/kg-d | Suppression of endothelin-1 secretion (suggestive of vasodilation); no effect on blood pressure; the study authors reported no “severe” side effects. | 4.3 | NDr | Predel et al. (1995); (Double-blind clinical trial.) | PR
Short term | 42 angina patients (40 M, 2 F). 30-mg extended-release tablets, either 2 or 4/d. 14 d. | 0, 0.86, 1.7 mg/kg-d | 6/42 had headache or flushing side effects, 2/42 had itching side effect. Reduction in angina attacks, reduction in chest pain, reduction in NTG use. It was not reported which effects occurred at which dose. | NDr | 0.86 | Roberts (1958); (Double-blind, placebo controlled clinical trial. Both doses grouped together for effects) | PR
Short term | 111 pregnant women with abnormal uterine blood flow: 57 placebo, 54 PETN. 12-wk duration, 80 mg 2 times/d. | 0, 2.3 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy). No significant increase in toxicologically relevant side effects observed. | NDr | 2.3 | Schleussner et al. (2014); (Double-blind, placebo-controlled clinical trial with random allocation.) | PR; the 2.3-mg/kg-d dose is considered a NOAEL for side effects.
Short term | 71 M, 9 F (80 total) coronary artery disease patients, 40 placebo, 40 PETN (80 mg 3 times/d). 8-wk duration. | 0, 3.4 mg/kg-d | Vasodilation measured by brachial arterial blood flow; the study authors did not report whether any toxicologically relevant side effects occurred during the trial. | NDr | 3.4 | Schnorbus et al. (2010); (Double-blind, placebo controlled clinical trial with random allocation. Side effects recorded in subject diaries, but not reported.) | PR
Short term | 19 M, 2 F (21 total) subjects completed the study. Each subject (alternating) took PETN, 30-mg tablets 4 times/d or placebo, 4 wk on, 4 wk off. 12-wk duration. | 0, 1.7 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); the study authors reported no “detectable differences” in incidence of toxicologically relevant side effects between PETN and placebo treatment. Incidence of side effects similar in both control and treated groups. No significant variations in blood pressure. | NDr | 1.7 | Aubert et al. (1970); (Double-blind placebo-controlled clinical trial, crossover design.) | PR; the 1.7-mg/kg-d dose is considered a LOAEL for vasodilatory effects and a NOAEL for side effects.
Short term | 10 M, 6 F (16 total) coronary artery disease patients and 5 healthy volunteer controls (sex not specified); time-release formulation (Duotrate), either 30-mg tablets 2 times/d or 45-mg tablets 2 times/d. Various durations up to 8 wk. | 0, 0.86, 1.3 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); 15/16 vs. 8/12 for the placebo group; side effects were not elevated compared with placebo. | NDr | 0.86 | Cass and Cohen (1961); (Clinical trial, placebo-controlled, blinding not reported. Extended-release formulation; concurrent NTG treatment.) | PR
Short term | 45 M, 27 F (72 total) coronary heart disease patients.; Weeks 1−2: placebo; Weeks 3−4: 0.86; Weeks 5−6: placebo; Weeks 7−8: 0.86, or 1.7; Note: 11 subjects increased to 1.7 mg/kg-d during second 2-wk period due to no improvement in angina symptoms during Weeks 3−4.; Dosing 2 × or 4 × 30-mg extended-release tablets every 12 h) | 0, 0.86, 1.7 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); 3/72 patients removed due to side effects at 0.86 mg/kg-d during PETN treatment (2 with headaches, other not specified). No reporting of toxicologically relevant side effects in remaining 69 patients during PETN or placebo treatment. Side effects not considered significant. | NDr | 0.86 | Hedges and Gordon (1965); (Single-blind placebo-controlled clinical trial, crossover design.) | PR, PS; the 0.86-mg/kg-d dose is considered a NOAEL for side effects.
Short term | 493 M, 162 F, stable angina patients (655 total). 248 M, 79 F placebo (327 total), 245 M, 83 F PETN (328 total). 12-wk duration; 80 mg, 2 times/d. | 0, 2.3 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); 10/328 PETN and 7/327 placebo subjects were removed from the study for reasons not well characterized by the study authors. Some toxicologically relevant side effects, similar in number in the PETN group to the placebo group, were reported but otherwise uncharacterized. Thus, the LOAEL applies to the vasodilatation effect, not the side effects. | NDr | 2.3 | Oelze et al. (2014); (Double-blind, multicenter, clinical trial with placebo control and random allocation. Most subjects were on several other drugs, including beta-blockers, antithrombotics, statins, and ACE inhibitors.) | PR
Short term | 50 angina patients, sex not reported; 30 mg 2 or 3 times/d; various durations up to 12 wk. | 0, 0.86, 1.3 mg/kg-d; 45 patients received 0.86 mg/kg-d, 5 received 1.3 mg/kg-d. Both time-release (Duotrate) and standard formulation PETN used. | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy). toxicologically relevant side effects: giddiness, light-headedness, vertigo, and palpations reported in 10/50, persistent in 1/50, leading to withdrawal from study. | NDr | 0.86 | Plotz (1960); (Clinical trial, placebo-controlled, crossover design, blinding not reported. Extended-release formulation of PETN; concurrent NTG treatment. The study authors did not report which side effects occurred at which dose.) | PR; the 0.86-mg/kg dose is considered a NOAEL for side effects.
Short term | 19 M, 1 F, angina patients. Each subject received placebo and both dose levels of PETN. Various durations up to 6 mo. 2 × 10-mg tablets 4 times/d for Dose 1; 3 × 10-mg tablets 4 times/d for Dose 2. | 0, 1.1, 1.7 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy). 6/20 patients experienced improved condition at the low dose. Other effects including toxicologically relevant side effects of headaches, drowsiness, and nausea at the high dose (absent when high-dose group reverted to low dose). | 1.1 (but see comment about 0.86-mg/kg-d dose) | 1.7 | Rosenberg and Michelson (1955); (Double-blind, placebo-controlled clinical trial, crossover design; concurrent treatment with NTG; study authors reported no anginal pain reduction at 0.86 mg/kg-d for 5 individuals in a previous trial [i.e., lack of therapeutic effect].) | PR; the 1.1-mg/kg-d dose was considered a NOAEL for side effects and the 1.7-mg/kg-d dose was considered a LOAEL for side effects.
Short term | 14 M, 6 F, coronary artery disease patients (12 placebo, 8 PETN); Note: Prior to double-blind study, all subjects had 1 wk titration with PETN to determine personal optimal dose, followed by 1 wk washout with the placebo, then 4 wk with PETN or placebo. PETN doses were 40, 60, or 80 mg, 4 times/d. | 0, 2.3, 3.4, 4.6 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); headache, first 2 wk: 6/8 PETN, 3/12 placebo; headache, second 2 wk: 5/8 PETN, 2/12 placebo. | NDr | 2.3 | Shrivastava et al. (1983); (Double-blind placebo-controlled clinical trial. Actual doses for each subject not reported.) | PR
Short term | 22 M, 14 F, angina patients. 4-wk duration; 10-mg tablet, 8 times/d. | 1.1 mg/kg-d | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); toxicologically relevant side effects were: 5 headache, 5 nausea, 3 dizziness, 1 insomnia, 1 drowsiness. 2 withdrew due to side effects (1 dizziness and palpitation, 1 anorexia and constipation). | NDr | 1.1 | Edson et al. (1961); (Double-blind clinical trial, no placebo control group.) | PR; the LOAEL applies to both the vasodilatation effect and side effects.
Short term | 37 healthy and 27 cardiovascular disease patients, sex not reported. Various durations up to 30 wk, 30−160 mg/d. Doses were increased incrementally for some subjects; others received high dose throughout. | 0.43, 0.86, 1.1, 1.4, 1.7, 2.0, 2.3 mg/kg-d; doses linked to effects primarily as averages for specific treatment groups within a range: average (range) = 100 (30−140), 101 (30−160), 112 (30−140), 125 (100−160) mg/d, corresponding to 1.4, 1.6, 1.8 mg/kg-d. | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); 7/10 patients showed partial relief of symptoms at the 100−101-mg/d dose, indicating therapeutic efficacy; decreased systolic blood pressure in 7/21 hypertensive subjects (dose not specified); 1/64 subjects in the 2.0-mg/kg dose group complained of worsening headaches and did not complete the study. No control group data reported. | NDr | NDr | Perlman (1952); (Clinical trial, no placebo control group. Poor reporting of cardiovascular outcomes; cannot determine exact doses or any endpoint.) | PR
Short term to subchronic | 21 M, 8 F, arteriosclerosis patients. 7−14 mo durations. 28 subjects, 10-mg tablets, 4/d; 1 subject 10 mg, 3 times/d; 8 subjects increased to 20 mg, 4 times/d. | 0.42−0.57, 1.1 mg/kg-d in 8 subjects; no control group. | Vasodilation with potential for reduced blood pressure (implicit from therapeutic efficacy); therapeutic effects for 23/29 patients at 0.57 mg/kg-d were categorized as fair (2), good (18), or excellent (3), based on decreased number of angina attacks and decreased need for NTG; 1/29 had slight nausea at 0.57 mg/kg-d, 1/29 had nausea and headache at 0.57 mg/kg-d. | NDr | 0.57 | Phillips (1953); (Clinical case series. No control [placebo] group; concurrent treatment with NTG.) | PR; the 0.57-mg/kg-d dose is considered a LOAEL for vasodilatory effects and a NOAEL for side effects.
Short term | 6 M, 4 F, inpatients with diseases other than coronary artery disease or other heart conditions. 4-wk duration; 10-mg tablet, 4 times/d, Weeks 1−2; 20 mg, 3 times/d, Weeks 3−4. | 2 wk at 0.57 mg/kg-d, 2 wk at 0.86 mg/kg-d | Decreased response to NTG challenge, suggestive of development of cross-nitrate tolerance, toxicological significance uncertain but doubtful. Headaches reported in some individuals but always associated with NTG challenge. | NDr | NDr | Schelling and Lasagna (1967); (Clinical trial [pre- and post-treatment]. No endpoints of toxicological significance for PETN treatment; cannot establish LOAEL or NOAEL because of comorbidities and lack of placebo group.) | PR
Short term | 10 healthy volunteers per group (60 mg, 3 times/d), 7 d. | 0, 2.6 mg/kg-d | 6% decrease in systolic blood pressure and 18% increase in heart rate following PETN administration, compared with pretreatment. No toxicologically relevant side effects reported. | NDr | 2.6 | Jurt et al. (2001); (Double-blind clinical trial with random allocation [pre- and post-treatment comparison with NTG].) | PR; the 2.6-mg/kg-d dose is considered a LOAEL for vasodilatory effects and a NOAEL for side effects.
Short term | 28 M healthy volunteers: 80 mg 3 times/d for 6 d | 3.4 mg/kg-d (subjects were their own controls) | 6% decrease in systolic blood pressure, 7% decrease in diastolic blood pressure, and increased blood flow in forearm following PETN therapy (compared with pretreatment). The study authors did not report whether any toxicologically relevant side effects occurred during the trial. | NDr | 3.4 | Gori et al. (2003); (Double-blind clinical trial with random allocation [pre- and post-treatment comparison with NTG].) | PR; the 3.4-mg/kg-d dose is considered a LOAEL for vasodilatory effects and a NOAEL for side effects.
Short term | 111 pregnant women (54 PETN, 57 placebo) at mid-gestation (average gestational age at start = 21.5 wk). 0 or 80 mg 2 times/d for 88−90 d | 0, 2.1 mg/kg-d; assuming an average body weight of 75 kg for pregnant women [see Table 8-29 in U.S. EPA (2011a)] | Vasodilation with potential for reduced blood pressure (implicit from the therapeutic effect of increased uteroplacental and fetoplacental perfusion). | NDr | 2.1 | Bowkalow et al. (2018); (Double-blind clinical trial with random allocation.) | PR; side effects not reported.
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
Short term | 5 M/5 F, F344/N rat, diet, 7 d/wk, 14 d; 0, 620, 1,240, 2,500, 5,000, or 10,000 ppm. | M: 0, 65.7, 129.0, 347.8, 674, 1,110; F: 0, 79.0, 168.0, 355.7, 635, 1,310 | No compound-related toxicologically relevant effects on mortality, clinical signs, body weight, or gross necropsy. | 1,310 (F) | NDr | Bucher et al. (1990); NTP (1989) | PR
Short term | 5 M/5 F, B6C3F1 mouse, diet, 7 d/wk, 14 d; 0, 620, 1,240, 2,500, 5,000, or 10,000 ppm. | M: 0, 173, 308.7, 539.7, 1,380, 2,600; F: 0, 187, 556.9, 703.1, 1,800, 2,530 | 58−85% decrease in body-weight gain in females; 13% decrease in terminal body weight at ≥1,800 mg/kg-d. | 703.1 (F) | 1,800 (F) | Bucher et al. (1990); NTP (1989) | PR
Short term | 6 (sex not specified), mongrel dog, gavage, 7 d/wk, 3 wk; 30 mg/d. | 1.3 | Coronary effects of uncertain biological significance (increased coronary vascular resistance and mechanical efficiency; reduced coronary blood flow, left ventricular oxygen consumption, and left ventricular work). | NDr | NDr | Bender et al. (1963) (Cannot determine toxicological relevance or lack thereof because effects are opposite of expected biological action [vasodilation].) | PR
Subchronic | 10 M/10 F, F344/N rat, diet, 7 d/wk, 14 wk; 0, 620, 1,240, 2,500, 5,000, or 10,000 ppm. | M: 0, 39.1, 88.04, 190.0, 330, 630; F: 0, 42.8, 85.56, 200.0, 370, 830 | Significant changes in body-weight gain and relative brain weight at concentration ≥200 mg/kg-d. | 85.56 (F) | 200.0 (F) | Bucher et al. (1990); NTP (1989) | PR
Subchronic | 10 M/10 F, B6C3F1 mouse, diet, 7 d/wk, 13 wk; 0, 620, 1,240, 2,500, 5,000, or 10,000 ppm. | M: 0, 109, 302.6, 362.5, 925, 2,140; F: 0, 172, 306.3, 632.5, 1,340, 3,120 | No observed noncancer effects. A hepatocellular adenoma was observed in 1 female mouse at 3,120 mg/kg-d. | 3,120 (F) | NDr | Bucher et al. (1990); NTP (1989) | PR
Chronic | 50 M/50 F, F344/N rat, diet, 7 d/wk, 2 yr; M: 0, 5,000, or 10,000 ppm; F: 0, 1,240, or 2,500 ppm. | M: 0, 240, 490; F: 0, 80, 165 | No observed effects. | 490 (M) | NDr | Bucher et al. (1990); NTP (1989) | PR
Chronic | 50 M/50 F, B6C3F1 mouse, diet, 7 d/wk, 2 yr; 0, 5,000, or 10,000 ppm. | M: 0, 810, 1,620; F: 0, 1,020, 1,936 | No observed effects. | 1,936 (F) | NDr | Bucher et al. (1990); NTP (1989) | PR
Chronic | 45 M + F (sex ratio not reported), albino rat, diet, 7 d/wk, 1 yr; 0 or 2 mg/kg-d. | 0, 2 | No observed effects. | NDr | NDr | Donahue (1944); (Confidence in study is low due to 50% mortality from parasitic infection in the colony.) | PR
Reproductive/Developmental | 10 M/10 F, Sprague Dawley rat, gavage in corn oil, 7 d/wk, 28 d in males (premating through mating), up to 56 d in females (premating through PND 3); 0, 100, 500, or 1,000 mg/kg-d. | 0, 100, 500, 1,000 | No observed effects. | 1,000 | NDr | Quinn et al. (2009); (Study did not report mating/fertility indices.) | PR
2. Inhalation (mg/m^3^)
ND

a Duration categories are defined as follows: Acute = exposure for ≤24 hours; short term = repeated exposure for >24 hours to ≤30 days; long term (subchronic) = repeated exposure for >30 days ≤10% lifespan for humans (>30 days up to approximately 90 days in typically used laboratory animal species); and chronic = repeated exposure for >10% lifespan for humans (>~90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002).

b Dosimetry: Doses are presented as ADDs (mg/kg-day), except single-dose studies where mg/kg doses are presented. Where applicable, reported body-weight data were used if available; if not, reference body-weight values for rodents reported by U.S. EPA (1988) were used; for humans, a default value of 70 kg was used, except for pregnant women, where 75 kg was used.

c Notes: PR = peer reviewed; PS = principal study.

ACE = angiotensin-converting enzyme; ADD = adjusted daily dose; cGMP = cyclic guanosine monophosphate; F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = no data; NDr = not determined; NOAEL = no-observed-adverse-effect level; NTG = nitroglycerin; PETN = pentaerythritol tetranitrate; PND = postnatal day.

Table 3B Summary of Potentially Relevant Cancer Data for PETN (CASRN 78-11-5)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry^a^ | Critical Effects | Reference | Notes^b^
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
Carcinogenicity | 50 M/50 F, F344/N rat, diet (0, 5,000, 10,000 ppm M: 0, 1,240, 2,500 ppm F); 2 yr | M: 0, 67.2, 137; F: 0, 20, 41.3 | Increases in Zymbal and thyroid gland tumors (dose related in females) | Bucher et al. (1990); NTP (1989) | PR, PS
Carcinogenicity | 50 M/50 F, B6C3F1 mouse, diet (0, 5,000, 10,000 ppm); 2 yr | M: 0, 122, 243; F: 0, 153, 290.4 | No exposure-related neoplastic lesions | Bucher et al. (1990); NTP (1989) | PR
2. Inhalation (mg/m^3^)
ND

a Dosimetry: The units for oral exposures are expressed as HEDs (mg/kg-day); HED = adjusted daily animal dose (mg/kg-day) × (BW_a_ ÷ BW_h_)^1/4^ (U.S. EPA, 2005), using study-specific TWAs (for the control, low-, and high-dose groups, respectively) of 0.433, 0.419, and 0.413 kg for male rats; 0.289, 0.276, and 0.284 kg for female rats; 0.0371, 0.0354, and 0.0369 kg for male mice; 0.0363, 0.0332, and 0.0368 kg for female mice; and 70 kg for humans (U.S. EPA, 2011c).

b Notes: PR = peer reviewed; PS = principal study.

BW = body weight; F = female(s); HED = human equivalent dose; M = male(s); ND = no data; PETN = pentaerythritol tetranitrate; TWA = time-weighted average.

## 2.1 HUMAN STUDIES

### 2.1.1 Oral Exposures

Data regarding oral PETN exposure in humans are available from numerous clinical studies. The therapeutic effects of oral PETN administration are similar to other nitrovasodilators that increase coronary blood supply to the heart and decrease myocardial oxygen demands through preferential dilation of large veins and arteries via smooth muscle relaxation (Klemenska and Beresewicz, 2009; Kosmicki, 2009; Daiber et al., 2008; Murad, 1990). Historically, the typical oral dosage of PETN used to treat angina pectoris has been 10−80 mg as a tablet up to 4 times daily or 30−80 mg as a sustained release capsule every 12 hours [Murad (1990); PDR (1987) as cited in NTP (1989)], with a total daily dose ranging from 30−320 mg/day (0.43−4.6 mg/kg-day for a 70-kg adult). Daiber and Münzel (2015) reported a usage of 50−80 mg per dose (therapeutic action of 8−12 hours), and recent clinical trials have evaluated daily doses of 160−240 mg/day (2.3−3.4 mg/kg-day for a 70-kg adult) (Münzel et al., 2014; Schleussner et al., 2014; Schnorbus et al., 2010). As noted in the “Mode of Action” section below, the therapeutic vasodilatory action of organic nitrates, including PETN, are attributed to their active intermediate, nitric oxide (NO) [reviewed by Daiber and Münzel (2015); Münzel et al. (2013); Kosmicki (2009); Daiber et al. (2008); Bode-Böger and Kojda (2005); Murad (1990)]. As discussed in the “Metabolism” section below, NO is released during PETN metabolism.

Most of the clinical studies in the PETN literature were designed to test the effectiveness of a generally continuous intake of the drug in alleviating angina pectoris. Dosing protocols consisted of administering 3 or 4 immediate-release tablets 3 or 4 times per day or 2 delayed/sustained-release tablets every 12 hours for durations ranging from 3 days to 30 weeks. Given the half-life of PETN for humans in the range of 4−8 hours (Weber et al., 1995) and a therapeutic action duration of 8−12 hours (Daiber and Münzel, 2015), the typical dosing protocols should result in a relatively constant effective internal concentration. Presentation of study results was almost always focused on symptomology rather than on explicit measures of specific endpoints, such as vasodilation or blood pressure. Therefore, the effectiveness of PETN in eliciting the primary therapeutic effect—vasodilation—is largely implicit in these studies for findings of efficacy in alleviating clinical symptoms. The effect (or lack of effect) on blood pressure, the endpoint of greatest concern for environmental exposures to the general population, was infrequently mentioned. Several acute-exposure studies, however, were designed to study vasodilation and blood pressure effects (Henstridge et al., 2009; Dragoni et al., 2007; Bohm and Haustein, 1998; Amsterdam et al., 1980; Shellock et al., 1980; Dagenais et al., 1969). In all those studies, blood pressure reductions were observed; see Table 3A.

The studies using multiple daily treatment protocols (“continuous-exposure” studies) generally reported efficacy of PETN in alleviating angina symptoms at the lowest treatment levels, which are designated as LOAELs in the general population for the critical effect of vasodilation, with the potential for reduced blood pressure. Referring to Table 3A, short-term to subchronic exposure-duration LOAELs for vasodilation in the range of 0.57−3.4 mg/kg-day (assuming a 70 kg adult) have been established (Oelze et al., 2014; Schleussner et al., 2014; Schnorbus et al., 2010; Shrivastava et al., 1983; Aubert et al., 1970; Hedges and Gordon, 1965; Cass and Cohen, 1961; Edson et al., 1961; Plotz, 1960; Rosenberg and Michelson, 1955;Phillips, 1953). In all but one of these studies, vasodilation was implicit (based on therapeutic efficacy). The one exception is the study of Schnorbus et al. (2010), which determined vasodilation by an increase in brachial artery blood flow at a dose level of 3.4 mg/kg-day. Two of the continuous-exposure studies established LOAELs for decreased blood pressure of 2.6 mg/kg-day (Jurt et al., 2001) and 3.4 mg/kg-day (Gori et al., 2003). LOAELs for two other continuous-exposure studies could not be established because either the treatment levels associated with the reported effects were not specified (Perlman, 1952) or the toxicological relevance of the reported effects could not be determined (Schelling and Lasagna, 1967). In the former case (Perlman, 1952), the therapeutic efficacy was evident (implicit vasodilation) and reduced blood pressure in 7/21 hypertensive subjects was reported, but the exact doses were not specified among several dose levels used, ranging from 30 mg/day to 160 mg/day. In the latter case (Schelling and Lasagna, 1967), the toxicological significance of the reported endpoint (decreased response to NTG challenge) could not be determined (see Table 3A). No NOAELs were identified in any of the continuous-exposure studies, although a NOAEL of 0.86 mg/kg-day was implied by Rosenberg and Michelson (1955), who reported no anginal pain reduction at 0.86 mg/kg-day for five individuals in a previous trial. A confounding factor in several of the studies was concurrent treatment with NTG or other drugs affecting cardiovascular activity (Oelze et al., 2014; Cass and Cohen, 1961; Plotz, 1960; Rosenberg and Michelson, 1955; Phillips, 1953). Thus, determining the exact contribution of PETN to the efficacy of the treatment in these studies is problematic. Notably, the lowest apparent LOAEL of 0.57 mg/kg-day was determined from the Phillips (1953) study, with concurrent NTG treatment, which excludes this value for consideration as a POD.

#### Side Effects

The term “side effect” is used in the document to largely include toxicologically relevant symptoms expressed by patients, including headache, nausea, dizziness, etc. This is distinct from hemodynamic signs, including blood pressure, heart rate, blood flow, etc., measured in patients. Side effects associated with therapeutic use of organic nitrates (including PETN) are well characterized and virtually all are considered to be secondary to the primary action of vasodilation [reviewed by Daiber et al. (2008); Bode-Böger and Kojda (2005); Murad (1990)]. In double-blind, placebo-controlled, randomized clinical trials following oral PETN administration, study participants exhibited side effects such as headaches (see also Table B-1) at NOAEL doses as low as 1.1 mg/kg-day (Rosenberg and Michelson, 1955). Other evidence from non-placebo-controlled studies, or inadequately reported studies, show increases in side effects at doses >2.3 mg/kg-day (Schelling and Lasagna, 1967). Evidence from the placebo-controlled studies of greater than 4 weeks showed NOAELs for side effects ranging from 0.86−2.3 mg/kg-day (Schleussner et al., 2014; Aubert et al., 1970; Hedges and Gordon, 1965). Additional data from studies lacking a placebo control or inadequately reported studies show putative NOAELs for side effects in the same range (0.57−2.3 mg/kg-day) [e.g., Phillips (1953); Perlman (1952)]. Headaches, sometimes severe, and nausea due to cerebral vasodilation are the most common side effects. Side effects generally occurred at doses higher than those associated with the therapeutic effect of vasodilation, though the NOAELs for side effects overlap the NOAELs and LOAELs for the primary vasodilation effect, and in Edson et al. (1961), the LOAEL for side effects was the same as the LOAEL for vasodilatation.

#### Blood Pressure Effects

Of particular interest is the potential for a reduction in blood pressure, which, although perhaps a beneficial effect for some cardiac patients, is a detrimental effect in the general population, particularly for those individuals susceptible to hypotension. The latter would include pregnant women, infants, the elderly, those with diabetes, and men on erectile dysfunction medication, among others. Blood pressure, however, is rarely measured in rodent studies. There are other studies in the database supporting this effect including the work of Bender et al. (1963) who reported mean arterial pressure in dogs, and the work with spontaneously hypertensive rats (Commarato et al., 1973) and related studies, see below.

### 2.1.2 Single-Dose (Acute) Studies

The human clinical studies reporting decreases in blood pressure have largely been single-dose administrations designed to study the acute hemodynamic activity of PETN, rather than as treatment for angina pectoris. The studies have been conducted with cardiac patients (Giles et al., 1981; Amsterdam et al., 1980; Shellock et al., 1980; Dagenais et al., 1969), pregnant women (Henstridge et al., 2009), and healthy volunteers (Henstridge et al., 2009; Dragoni et al., 2007; Bohm and Haustein, 1998) alike. Because of uncertainties of the effective half-life of PETN, the dosimetry here is shown as actual dose. Five of the seven single-dose studies reported reduced systolic (or “systemic”) blood pressure in the range of 5−14% at doses ranging from 20−80 mg. In one double-blind study, Dagenais et al. (1969), reported a 5−10% reduction in blood pressure for 15 angina patients following a single dose of 20 mg PETN.^1^ Another study showing acute effects of PETN on hemodynamic parameters is Amsterdam et al. (1980), who reported a 7−14% reduction in blood pressure for 12 healthy volunteers given a single dose of 40 mg (also a double-blind design). In addition, Bohm and Haustein (1998) reported a 7% reduction in blood pressure at a dose of 80 mg for 12 healthy volunteers, but no effects at doses of 25 or 50 mg. In a study in pregnant women, significant reductions in blood pressure and compensatory increase in heart rate occurred within 15 minutes of treatment of 160 mg (Henstridge et al., 2009). Conversely, one of the single-dose studies reported no effect on blood pressure at doses of 40 mg in 10 angina patients (Giles et al., 1981). These effects on hemodynamic parameters represent the proximal effects of PETN, and because they appear in acute as well as longer term studies, indicate less of an effect for duration of exposure on the severity of the effect than is typically the case.

### 2.1.3 Continuous Exposure Studies

Only 3 (Gori et al., 2003; Jurt et al., 2001; Perlman, 1952) of the 16 multiple-daily-dose studies reported reductions in blood pressure. Two of the studies (Gori et al., 2003; Jurt et al., 2001) were designed to evaluate PETN for development of tolerance and potential for oxidative stress, relative to NTG, rather than to evaluate the clinical efficacy of PETN for treatment of angina. The two studies were conducted in the same laboratory with healthy volunteer subjects and used double-blind protocols (Gori et al., 2003; Jurt et al., 2001). Although Jurt et al. (2001) used a separate control group, the subjects in the Gori et al. (2003) study were their own controls (before and after measurements). Gori et al. (2003) found that both PETN and NTG increased forearm blood flow, but that, unlike NTG, repeated PETN treatment was not associated with the development of tolerance or presence of oxidative stress markers. Jurt et al. (2001) reported an average 6% reduction in systolic blood pressure associated with PETN treatment at 2.6 mg/kg-day (60 mg, 3 times daily for 7 days). Gori et al. (2003) confirmed the vasodilatory action and lack of development of tolerance for PETN and reported a 6−7% reduction in both systolic and diastolic blood pressure for 28 healthy male volunteers administered PETN at 3.4 mg/kg-day (80 mg, 3 times daily for 6 days). Both sets of investigators reported no side effects. The third multiple-daily-dose study reporting blood pressure effects was a clinical trial investigating the efficacy of PETN for 27 cardiovascular patients and the potential for side effects in 37 healthy volunteers (Perlman, 1952) at dose levels from 0.43−2.3 mg/kg-day, with treatment durations up to 30 weeks. Perlman (1952) reported that systolic blood pressure was reduced in 7 of 21 hypertensive subjects, presumably from the cardiovascular patient group (but not specified as such); neither the magnitude of the decrease nor the effective dose level(s) was reported. Of the other 13 multiple-daily-dose studies, only 2 specifically reported that blood pressure was not affected (Schleussner et al., 2014; Predel et al., 1995). There was no mention of blood pressure endpoints in the remaining 11 studies.

### 2.1.4 Inhalation Exposures

No human studies following inhalation exposure to PETN have been identified.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures

#### Short-Term Studies

##### Bucher et al. (1990); NTP (1989) (Rat Study)

F344/N rats (five/sex/dose) were fed diets containing 0, 3,100, 6,200, 12,500, 25,000, or 50,000 ppm of National Formulary (NF) Grade PETN (PETN NF), a 1:4 formulation of PETN (purity >99%) and D-lactose monohydrate, typically used in human therapeutics, for 14 days. Equivalent PETN concentrations were 0, 620, 1,240, 2,500, 5,000, or 10,000 ppm, respectively. Based on the average of the reported initial and final body weights and food-consumption data from Day 7, the average daily consumption of PETN calculated for this review was 65.7, 129.0, 347.8, 674, or 1,110 mg/kg-day, respectively, in males and 79.0, 168.0, 355.7, 635, or 1,310 mg/kg-day, respectively, in females. The animals were observed twice daily for mortality and clinical signs of toxicity. Body weight was measured weekly and food consumption monitored throughout the study. Gross necropsy was performed on all animals at sacrifice.

Terminal body weights were within 5% of control in all treated groups (see Table B-2). The study authors indicated that there were “no clinical signs or toxic lesions” related to exposure. No further details were provided.

The NOAEL of 1,310 mg/kg-day in females is identified based on a lack of reported effects.

##### Bucher et al. (1990); NTP (1989) (Mouse Study)

B6C3F1 mice (five/sex/dose) were fed diets containing 0, 3,100, 6,200, 12,500, 25,000, or 50,000 ppm PETN NF (0, 620, 1,240, 2,500, 5,000, or 10,000 ppm PETN) for 14 days. Based on the average of the reported initial and final body weights and food-consumption data from Day 7, the average daily consumption of PETN calculated for this review was 173, 308.7, 539.7, 1,380, or 2,600 mg/kg-day, respectively, in males and 187, 556.9, 703.1, 1,800, or 2,530 mg/kg-day, respectively, in females. The animals were observed twice daily for mortality and clinical signs of toxicity. Body weight was measured weekly and food consumption monitored throughout the study. Gross necropsy was performed on all animals at sacrifice. Microscopic histopathology was limited to the kidney from the control and the two highest dose groups.

All mice survived until sacrifice. No clinical signs of toxicity were reported. Terminal body weight was significantly decreased by 13% in the highest dosed females, compared with control; body-weight gain significantly decreased by 58−85% in females at ≥1,800 mg/kg-day (statistics performed for this review; see Table B-2). The study authors indicated that no exposure-related gross or microscopic lesions were observed.

A NOAEL of 703.1 mg/kg-day and a LOAEL of 1,800 mg/kg-day are identified based on a statistically significant 58% decrease in terminal body-weight gain in female mice.

##### Bender et al. (1963)

Six mongrel dogs (sex not specified) were administered PETN at a dose of 30 mg via gavage daily for 3 weeks (vehicle and purity not reported). Based on the average reported body weights (15.0−30.5 kg), the estimated daily dose is 1.3 mg/kg-day. Body weight, respiratory rate and ventilator volume, blood oxygen content, and various cardiovascular endpoints (coronary blood flow, cardiac output, oxygen consumption, left ventricular work, mean arterial pressure, mean pulmonary artery pressure, mean coronary sinus pressure, and mechanical efficiency) were determined before the daily PETN administration and after the final PETN administration on Day 21.

A statistically significant 2.3% decrease in body weight was observed following PETN exposure, compared with pre-exposure values. No significant changes were observed in respiratory rate, ventilator volume, or blood oxygen content. The observed decrease in body weight is not considered biologically relevant because the effect was small (<10%). No significant changes were observed in systemic blood pressure values. Significant increases were observed in local cardiac effects including coronary vascular resistance and mechanical efficiency, while significant reductions were observed in other local cardiovascular indicators including coronary blood flow, left ventricular oxygen consumption, and left ventricular work. The coronary fractional flow (coronary blood flow/cardiac output) was significantly decreased by 37%. Because the coronary effects are in the opposite direction of the expected action of PETN (vasodilation), the biological significance of the observed cardiac effects is not clear.

Because of the uncertainty in the biological significance of the cardiac effects, a NOAEL or LOAEL cannot be identified for this study.

#### Subchronic Studies

##### Bucher et al. (1990); NTP (1989) (Rat Study)

F344/N rats (10/sex/dose) were fed diets containing 0, 3,100, 6,200, 12,500, 25,000, or 50,000 ppm of PETN NF (0, 620, 1,240, 2,500, 5,000, or 10,000 ppm PETN) for 14 weeks. Based on the reported daily food consumption per kilogram of body weight at Week 7, the average daily consumption of PETN calculated for this review was 39.1, 88.04, 190, 330, or 630 mg/kg-day, respectively, in males and 42.8, 85.56, 200, 370, or 830 mg/kg-day, respectively, in females. The animals were observed twice daily for clinical signs of toxicity. Body weights were recorded at study initiation, once per week during the study, and at necropsy. Feed consumption was measured 2−3 days per week. At necropsy, blood was collected for whole-blood methemoglobin (MetHb) concentration. All animals were grossly examined, and the brain, heart, right kidney, liver, lungs, and thymus were removed and weighed. Comprehensive histological examinations were conducted in the control and highest dose groups of both sexes; evaluations at lower doses were limited to the Zymbal gland in females at 370 mg/kg-day.

No mortalities or clinical signs of toxicity were reported. A statistically significant 6−7% decrease in terminal body weight was observed in females at ≥370 mg/kg-day, and a statistically significant decrease in total body-weight gain was observed in females at ≥200 mg/kg-day (12% at 200 mg/kg-day, 17% at 370 mg/kg-day, and 18% at 830 mg/kg-day), compared with controls (statistics performed for this review; see Table B-3). No body-weight effects were observed in males (see Table B-3). MetHb levels were <1% in all control and exposed groups. In females, relative brain weights were increased significantly by 6−8% at ≥200.0 mg/kg-day, compared with controls, and relative kidney weights were significantly increased by 6% at 830 mg/kg-day, compared with controls (see Table B-3); absolute organ weights were not reported. No additional organ-weight effects were noted in females, and no dose-related organ-weight effects were observed in males (see Table B-3). No exposure-related non-neoplastic gross or histopathological lesions were observed. An adenoma of the Zymbal gland was observed in one female rat at 830 mg/kg-day.

The decreases in body weight for females did not exceed 10% and are not considered to be biologically significant. The increases in relative kidney weights for females are also not considered toxicologically relevant because they were less than 10%. The increases in relative brain weight and the 12% decrease in body-weight gain are considered to be toxicologically relevant. The NOAEL of 85.56 and LOAEL of 200 mg/kg-day are identified based on increased relative brain weight and decreased body-weight gain in female rats.

##### Bucher et al. (1990); NTP (1989) (Mouse Study)

B6C3F1 mice (10/sex/dose) were fed diets containing 0, 3,100, 6,200, 12,500, 25,000, or 50,000 ppm PETN NF (0, 620, 1,240, 2,500, 5,000, or 10,000 ppm PETN) for 13 weeks. Based on the average of the daily feed-consumption data for Weeks 7 and 13, the average daily consumption of PETN calculated for this review was 109, 302.6, 362.5, 925, or 2,140 mg/kg-day, respectively, for males and 172, 306.3, 632.5, 1,340, or 3,120 mg/kg-day, respectively, for females. Clinical signs, body weights, feed consumption, and whole-blood MetHb concentrations were evaluated as reported above for rats. Necropsies and measurements of brain, heart, right kidney, liver, lungs, and thymus weights were performed on all animals. Comprehensive histological examinations were conducted in the control and highest dose groups of both sexes; histological evaluations at lower doses were limited to the liver in females at 1,340 mg/kg-day.

No mortalities, clinical signs of toxicity, or body-weight effects were reported. MetHb levels were <1% in all control and exposed groups. In highest dosed females, relative liver and kidney weights were slightly, but significantly, increased by 7−8%, compared with controls (see Table B-4); absolute organ weights were not reported. No additional organ-weight effects were noted (see Table B-4). No exposure-related gross or histopathological lesions were observed. A hepatocellular adenoma was observed in one female mouse at 3,120 mg/kg-day.

The highest dose used is a NOAEL of 3,120 mg/kg-day in females, identified for the lack of dose-related toxicologically relevant effects. The minor increases in relative liver and kidney weights in females are not considered toxicologically relevant effects due to their small magnitude (<10%).

#### Chronic/Carcinogenicity Studies

##### Bucher et al. (1990); NTP (1989) (Rat Study)

F344/N rats (50/sex/dose) were fed diets containing PETN NF for 2 years. Males were fed dietary concentrations of 0, 25,000, or 50,000 ppm PETN NF (0, 5,000, or 10,000 ppm PETN) and females were fed dietary concentrations of 0, 6,200, or 12,500 ppm (0, 1,240, or 2,500 ppm PETN). The lower dietary concentrations of PETN NF were selected for the female rats because higher concentrations caused 12−18% decreases in body-weight gains in the 14-week study summarized above. Bucher et al. (1990) reported an average daily PETN consumption of approximately 240 or 490 mg/kg-day in males and 80 or 165 mg/kg-day in females, respectively. Clinical signs, body weights, and feed consumption were evaluated throughout the study. Necropsies were performed on each rat. Comprehensive histological examinations were performed on low-dose rats that died before Month 21 and on all control and high-dose rats. Histological examinations in the remaining low-dose rats were limited to the liver, kidneys, and gross lesions in both sexes; the brain, pancreas, and testes in males; and the esophagus, lungs, thyroid, and uterus in females.

No exposure-related changes were observed in survival, clinical signs, or feed consumption. Mean body weights were 2−9% lower in high-dose males throughout the study, compared with controls; terminal body weights were 7% lower than controls (statistics not reported; data reporting was inadequate for independent statistical review). Mean body weights for the low-dose males and all dosed females remained within 5% of control values throughout the study. No exposure-related non-neoplastic lesions were observed in either sex.

Adenomas or carcinomas of the Zymbal gland occurred in all chronically treated groups of male and female rats, but the incidences were low and did not demonstrate statistical significance when compared with controls. However, females had a significant dose-related trend in adenomas or carcinomas (see Table B-5). The incidences of Zymbal gland neoplasms exceeded the mean historical incidences for each sex, (see Table B-5). There were no increases in hyperplasia to suggest an increase of proliferative lesions of the Zymbal gland. Based on the occurrence of 9% Zymbal gland neoplasms in the high-dose female rats compared with none in controls, a statistically significant trend in females, (p = 0.028), and the occurrence of a Zymbal gland tumor in one high-dose female rat, (1/10 compared with 0/10 in controls) in the 14-week study summarized above, the study authors concluded that the results of the chronic study suggested a possible PETN-related effect.

Thyroid gland follicular cell adenomas or carcinomas (combined) were observed only in high-dose female rats (3/50). Although this incidence was not significantly increased compared with controls (0/50), there was a statistically significant dose-related trend in females and it exceeded historical control incidences (see Table B-5). Because there were no indications of increased follicular cell adenomas or carcinomas, or increased follicular cell hyperplasia in males, the NTP study authors did not consider the marginal increase in follicular cell tumors in females to be related to PETN. However, for the purposes of this PPRTV assessment, the U.S. EPA considers these thyroid tumors to be treatment related.

Other neoplastic findings included mononuclear leukemia in male rats that occurred with a negative trend due to an incidence in the high-dose group that was significantly lower than in controls.

A NOAEL of 10,000 ppm (490 mg/kg-day) is identified in male rats based on a lack of exposure-related noncancer effects. The body-weight decreases observed in high-dose males are not considered toxicologically relevant due to the small magnitude of effect (<10%). NTP concluded that there was “Equivocal Evidence of Carcinogenic Activity” of PETN in both male and female rats based on the increase in neoplasms of the Zymbal gland exceeding historical controls.

##### Bucher et al. (1990); NTP (1989) (Mouse Study)

B6C3F1 mice (50/sex/dose) were fed diets containing 0, 25,000, or 50,000 ppm PETN NF (0, 5,000, or 10,000 ppm PETN) for 2 years. Bucher et al. (1990) reported an average daily PETN consumption of approximately 810 or 1,620 mg/kg-day in males and 1,020 or 1,936 mg/kg-day in females. Clinical signs, body weights, and feed consumption were evaluated throughout the study. Necropsy was performed on each mouse. Comprehensive histological examinations were performed on low-dose mice that died before Month 21 and on all control and high-dose mice. Histological examinations in the remaining low-dose mice were limited to the stomach and gross lesions in both sexes, and the liver and spleen in females.

There were no exposure-related decreases in survival, clinical signs, effects on body weight or food consumption, or increases in non-neoplastic or neoplastic lesions. Combined tumors of the subcutaneous tissues (primarily fibromas and fibrosarcomas) occurred with a negative dose-related trend in male mice; incidences in both dosed groups were significantly lower than in controls. Skin tumors in the male mice control group occurred at a rate nearly five times higher than in historical controls, but the study authors did not provide a rationale for this discrepancy.

For non-neoplastic effects, a NOAEL of 1,936 mg/kg-day in female mice is identified based on a lack of exposure-related effects. There was no evidence of carcinogenicity in male or female mice under the conditions of this bioassay.

##### Donahue (1944)

Male and female albino rats (45/group; sex ratio not reported) were fed PETN at dietary doses of 0 or 2 mg/kg-day for 1 year. Body weights were recorded weekly. Blood was collected monthly from 20 rats/group for hematology (erythrocyte count, hemoglobin [Hb] concentration total, and differential leukocyte counts). After the exposure period, the surviving animals were sacrificed. The liver, kidneys, spleen, heart with lungs, brain, and testes were removed, and the weight, volume, and density (ratio of weight to volume) were recorded. Histopathological examinations were performed on the liver, kidneys, spleen, heart, lungs, brain, and femur; the study authors noted that particular attention was paid to histological changes in the vascular walls of these tissues. Organs from animals that died before the scheduled sacrifice do not seem to have been examined.

High mortality (46.6% in the control group and 20% in the exposed group) was attributed to an infestation of parasitic tapeworm larvae observed in the livers of a large number of surviving rats (11/24 surviving controls, 12/36 surviving exposed). However, no data were provided regarding the presence or absence of parasitic infection in animals that died before the scheduled sacrifice. Body weights and growth curves were comparable between groups throughout the study. Erythrocyte and Hb values fluctuated throughout the study but remained within normal ranges for both control and exposed rats. Leukocyte values were abnormally high in both groups; the study authors attributed this finding to the observed parasitic infection. There were no exposure-related changes in organ weights, volumes, or density. No exposure-related histopathological lesions were observed.

A NOAEL or LOAEL are not identified from this study because confidence in this study is low due to the observed parasitic infestation and high mortality in both the control and exposure groups.

#### Reproductive/Developmental Studies

##### Quinn et al. (2009)

Groups of Sprague Dawley rats (10/sex/group) were administered PETN (purity >98%) at daily doses of 0, 100, 500, or 1,000 mg/kg-day via gavage in corn oil for up to 56 days. Dosing began 2 weeks prior to mating and continued in both sexes during mating. After mating, dosing of males continued until a total dosing period of 28 days was completed, whereupon they were sacrificed. Female exposure continued through gestation until Postnatal Day (PND) 3; dams with offspring were sacrificed on PND 4. During the exposure period, the animals were observed daily for mortality and clinical signs of toxicity. Parental body weights were recorded weekly. During premating, pregnancy, and lactation, food consumption was measured weekly. During the mating period, pregnancy was indicated by presence of a sperm plug. Dams were allowed to deliver, and the litters were examined for the number and sex of pups, number of live and dead pups, number of runts, and presence of gross abnormalities. Live pups were counted and sexed, and litter weights were recorded on PNDs 1 and 4. At sacrifice, all parental animals and offspring were examined grossly. The testes and epididymides of all male parental animals were removed and weighed. The ovaries, testes, epididymides, and all organs showing macroscopic lesions from parental animals were examined microscopically.

No exposure-related mortalities were observed; four animals died during the exposure period due to gavage error (esophageal perforation). No clinical signs of toxicity were observed. Male body weights and food consumption were comparable between the exposure and control groups throughout the study. Body weights were significantly elevated by 3−9% in females exposed to 100 or 500 mg/kg-day on Day 20 of exposure (approximately the end of the mating period) and at necropsy, compared with control; female body weights were comparable to control at the high dose throughout the study. Increased body weights in females at 100 and 500 mg/kg-day were accompanied by significant 43−57% increases in food consumption during premating and pregnancy.

The study authors did not report mating or fertility indices, and the total number of pregnant females and litters produced per group was not reported. No changes in gestation duration, number of pups, or pup sex ratio were observed. On PND 1, male pup body weights were significantly elevated by 6% at 500 mg/kg-day; however, body weights were comparable to control at 100 and 1,000 mg/kg-day on PND 1 and in all dose groups on PND 4. No exposure-related changes were observed in female pup body weights. No exposure-related gross deformities or lesions were observed in offspring, but traditional microscopic developmental outcome analyses in pups were not performed.

In parental animals, there were no exposure-related changes in relative testes, epididymides, or ovary weights (absolute weights not reported). No gross lesions were observed in adult males or females at necropsy, and no exposure-related histological lesions were observed in the testes, epididymides, or ovaries. The numbers of corpora lutea and implants were comparable between control and exposed females.

A NOAEL of 1,000 mg/kg-day is identified based on a lack of toxicologically relevant effects in reproductive organs in parental animals, litter parameters, or neonatal pup body weight, survival, or gross morphology.

### 2.2.2 Inhalation Exposures

No repeated-exposure inhalation studies have been identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

### 2.3.1 Genotoxicity

Table 4 provides an overview of genotoxicity studies of PETN. “Military-grade” PETN solutions in dimethylsulfoxide (DMSO) did not induce reverse mutations in Salmonella typhimurium when tested without metabolic activation in a spot test, or with metabolic activation in a plate incorporation assay (Whong et al., 1980). Similarly, the pharmaceutical-grade 1:4 PETN-lactose mixture used in the NTP toxicity and carcinogenicity studies (PETN NF) was not mutagenic in S. typhimurium when tested with or without metabolic activation in a preincubation assay (NTP, 1989; Mortelmans et al., 1986).

PETN NF induced a 17−31% increase in sister chromatid exchanges (SCEs) in cultured Chinese hamster ovary (CHO) cells in the presence and absence of metabolic activation; however, the response was not dose related and cell cycle delay was not induced (NTP, 1989). The lack of a dose-response may have been due to precipitation of the test compound at mid- and high-dose levels (NTP, 1989). PETN NF did not induce chromosomal aberrations (CAs) in CHO cells when tested with or without metabolic activation (NTP, 1989).

Table 4 Summary of PETN Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References
Genotoxicity studies in prokaryotic organisms
Mutagenicity | Salmonella typhimurium strains TA98, TA100, TA1535, TA1537, TA1538 | 0, 0.625, 1.25 mg/spot | − | ND | Spot test; test substance was military-grade PETN. | Whong et al. (1980)
Mutagenicity | S. typhimurium strains TA98, TA100, TA1535, TA1537, TA1538 | Up to 2.5 mg/plate | ND | − | Plate incorporation assay; test substance was military-grade PETN. | Whong et al. (1980)
Mutagenicity | S. typhimurium strains TA98, TA100, TA1535, TA1537 | 0, 100, 333, 1,000, 3,333, 10,000 µg/plate | − | − | Preincubation assay; test substance was pharmaceutical-grade PETN NF (1:4 PETN-lactose mixture); precipitate was noted at 10,000 µg/plate. | NTP (1989); Mortelmans et al. (1986)
Genotoxicity studies in mammalian cells―in vitro
SCE | CHO cells | 0, 160, 500, 1,600, 2,500 µg/mL | + | + | Test substance was pharmaceutical-grade PETN NF (1:4 PETN-lactose mixture). All concentrations induced a 17−31% increase in SCEs with and without metabolic activation, compared with controls; however, the response was not dose related and cell cycle delay was not induced. Precipitate was noted at ≥500 µg/plate. | NTP (1989)
CA | CHO cells | 0, 1,000, 1,600, 2,500 µg/mL | − | − | Test substance was pharmaceutical-grade PETN NF (1:4 PETN-lactose mixture). CAs were not induced in the presence or absence of S9 activation. | NTP (1989)

a + = positive; − = negative; ND = no data.

CA = chromosomal aberration; CHO = Chinese hamster ovary (cell line cells); PETN = pentaerythritol tetranitrate; PETN NF = National Formulary (NF) Grade PETN; SCE = sister chromatid exchange.

### 2.3.2 Additional Animal Studies

#### Acute Toxicity Studies

Several acute animal studies have evaluated cardiovascular endpoints following exposure to PETN. Statistically significant coronary artery dilation was observed in dogs following acute oral exposure to 9−12 mg/kg. Daily administration for 5 days did not result in nitrate tolerance (Fink and Bassenge, 1997; Bassenge et al., 1996). Observed effects in dogs exposed to lower doses (~0.4−0.8 mg/kg) included decreased coronary blood flow and reduced cardiac work load (Sullivan et al., 1964). Transient decreases in systemic blood pressure were also observed in most studies in rabbits, cats, and dogs following single oral exposures to 0.4−50 mg/kg (Mullenheim et al., 2001; Commarato et al., 1973; Banerjee et al., 1970; Sullivan et al., 1964; von Oettingen and Donahue, 1944); however, mean arterial pressure was not significantly decreased in dogs following exposure to 12 mg/kg (Bassenge et al., 1996). Decreased pulmonary arterial pressure, as well as bronchodilation, has also been reported in dogs following inhalation of low aerosol levels ranging from 11−225 µg; however, systemic cardiovascular changes (e.g., decreased heart rate, decreased systemic blood pressure) were not observed (Aviado et al., 1969).

Acute studies evaluating endpoints other than cardiovascular are limited to a single case study in a dog that ingested an unknown quantity of PETN while training to detect explosives (Potocnjak et al., 2008). The dog presented with central nervous system (CNS) depression, including bradycardia, swaying gait and broad-based stance, proprioceptive deficits in hind limbs, ataxia, inability to stand, and disorientation. Clinical tests showed transient mild anemia, increased urinary bilirubin, and increased serum levels of aspartate aminotransferase (AST), alanine aminotransferase (ALT), alkaline phosphatase (ALP), and gamma glutamyl transferase (GGT). The dog fully recovered after 1 week.

#### Studies Evaluating Actions of PETN in Animal Models of Cardiovascular Disease

Additional actions of PETN on the cardiovascular system have been studied using animal models of cardiovascular disease, including atherosclerosis (in cholesterol-fed rabbits) and hypertension (in N omega-nitro-L-arginine methyl ester [ʟ-NAME] spontaneously hypertensive rats).

Studies in atherosclerotic rabbit models have suggested that PETN treatment may slow or prevent the formation of atherosclerotic lesions. In cholesterol-fed rabbits, dietary exposure to 6 mg/kg-day PETN for 15 weeks protected against the development of aortic atherosclerosis and endothelial dysfunction without affecting the vasodilatory potency of PETN in aortic rings (Kojda and Noack, 1995; Kojda et al., 1995). The results of a subsequent study in cholesterol-fed rabbits indicated that dietary exposure to 6 mg/kg-day PETN for 16 weeks reduced the progression of aortic lesion formation, endothelial dysfunction, and low-density lipoprotein (LDL) oxidation in established atherosclerosis (Hacker et al., 2001). Kojda et al. (1998) proposed that the observed reductions in vascular superoxide production following exposure to 6 mg/kg-day PETN for 16 weeks contributes to the observed protective effects of PETN in experimental atherosclerosis.

Evidence for therapeutic benefits of PETN treatment in hypertensive rat models are inconsistent. In spontaneously hypertensive rats, acute exposure to 30 mg/kg resulted in a statistically significant decrease in systolic blood pressure 15 minutes after administration, with blood pressure values returning to near-control levels by 30 minutes after administration (Commarato et al., 1973). Similarly, studies in hypertensive Wistar rats found that exposure to PETN at twice daily doses of 50 mg/kg for 6 weeks resulted in a statistically significant 5% decrease in systolic blood pressure (Torok and Kristek, 2002; Kristek, 2000). Significant alterations in cardiovascular system parameters by PETN included reduced wall thickness of the thoracic aorta, carotid artery, and septal branch of the left descending coronary artery; reduced cross-sectional area of the carotid artery; increased inner diameter of the thoracic artery; and decreased wall: diameter ratio in the thoracic and carotid arteries. In contrast, subchronic studies in spontaneously hypertensive rats did not find any changes in general cardiovascular system parameters (including blood pressure or the geometry of conduit arteries, including inner diameter, wall thickness, or cross-sectional area of the thoracic aorta, carotid artery, and coronary artery) following exposure to PETN at once or twice daily doses of 100 mg/kg via gavage for 6 weeks (Dovinová et al., 2009; Gerová et al., 2005). However, Kristek et al. (2003) reported increased blood platelet cyclic guanosine 3c,5c-monophosphate (cGMP) content and decreased aortic nitric oxide synthase (NOS) activity.

While evidence for reduced blood pressure in hypertensive rats following PETN exposure is inconsistent, limited evidence suggests that pre- and postnatal exposure to PETN may have lasting effects on blood pressure and endothelial function. Following maternal exposure to 50 mg/kg-day during pregnancy and lactation, female offspring of spontaneously hypertensive rats show a persistent reduction in blood pressure in adulthood along with enhanced NO-mediated vasodilation in response to acetylcholine (Wu et al., 2015). No changes in blood pressure were observed in dams or male offspring.

### 2.3.3 Metabolism/Toxicokinetic Studies

#### Absorption and Distribution

In humans, oral absorption of PETN is relatively rapid. Davidson et al. (1970) and Davidson et al. (1971) identified radioactivity in the blood within 15 minutes of oral administration of radiolabeled PETN in humans, with peak blood radioactivity between 2−8 hours. Blood levels declined to about 40 and 10% of the peak level at 24 and 48 hours, respectively, with half-lives estimated in the range of 7.1−8.3 hours (Davidson et al., 1971). In another study, peak blood levels were achieved between 2 and 3 hours, with a plasma elimination half-life of 4−5 hours (Weber et al., 1995). Based on data in ligated rats, PETN is absorbed very slowly in the stomach, with increased rate of absorption in the intestines (DiCarlo et al., 1967). Initially (within 2 hours of administration), absorption is more rapid in the small intestine than the large intestine; however, the rate and extent of absorption in the large intestine increases between 2 and 4 hours. This shift in absorption is attributed to the extensive degradation of PETN into denitrated metabolites by bacterial flora in the large intestine; very little breakdown of PETN was observed in the stomach and small intestine (DiCarlo et al., 1967). Consistent with human data, maximal levels of radioactivity in the blood occur in rodents within 4 hours of oral administration of radiolabeled PETN [reviewed by Litchfield (1971)]. After absorption, PETN binds to both plasma proteins and erythrocytes, and is rapidly distributed throughout the body, with organ radioactivity levels greater than blood levels after 1 hour [reviewed by NTP (1989); Litchfield (1971)]. Absorption and distribution data are consistent with observed therapeutic effects, with peak vasodilatory effects of organic nitrates occurring 60−90 minutes following oral administration, with a duration of action of 3−6 hours [reviewed by Murad (1990)].

#### Metabolism

The metabolism of PETN has been extensively studied; a summary of available data is presented below based on the following reviews: Daiber et al. (2008), Daiber et al. (2004), Daiber and Münzel (2015), Gori and Daiber (2009), Münzel et al. (2013), Klemenska and Beresewicz (2009), NTP (1989), Litchfield (1971), Murad (1990), and Münzel and Gori (2013). PETN is sequentially denitrated to form pentaerythritol trinitrate (PETriN, CASRN 1607-17-6), pentaerythritol dinitrate (PEDN, CASRN 1607-01-8), pentaerythritol mononitrate (PEMN, CASRN 1607-00-7), and pentaerythritol (PE, CASRN 115-77-5), releasing a molecule of inorganic nitrite at each denitration step. In humans, PEDN and PEMN are the primary compounds detected in blood following oral administration, with only trace amounts of PETriN; the parent compound has not been quantified in the blood. This may be due, in part, to the breakdown of PETN and PETriN by intestinal microorganisms before absorption. In vitro, PETN metabolism has been shown to occur in the blood (primarily in red blood cells [RBCs]), in subcellular fractions of the heart, by liver parenchymal and reticuloendothelial cells, and in isolated aortas. At low concentrations (<1 µM), PETN is sequentially denitrated by mitochondrial aldehyde dehydrogenase 2 (ALDH-2), and the nitrite molecules released during metabolism are reduced to NO in the mitochondria via various pathways. At higher concentrations, PETN and its denitrated metabolites can also be metabolized by cytochrome P450 (CYP450) in the smooth endoplasmic reticulum, leading to the generation of NO. Denitrated metabolites can be glucuronidated before excretion, and evidence from biliary cannulated rats indicated that glucuronidated metabolites can undergo enterohepatic circulation via reabsorption from the intestines after removal of glucuronic acid.

#### Excretion

Excretion is primarily via urine and feces, with negligible excretion of breakdown products via the lungs (Davidson et al., 1971; Litchfield, 1971; Davidson et al., 1970). In humans given a single 20-mg dose, mean urinary excretion was 53.1% of the administered dose after 24 hours and 60.3% after 48 hours, and mean fecal excretion was 31.5% of the administered dose after 48−72 hours (Davidson et al., 1970). Similar proportions were observed following a single 40-mg dose (49.8% of administered dose in urine after 48 hours and 41.2% of administered dose in feces after 72 hours) (Davidson et al., 1971). The primary compounds identified in urine were PEMN and PE, while PETN and PE were the primary compounds in feces (see Table 5) (Davidson et al., 1971, 1970). The presence of PETN in feces was attributed to unabsorbed and unmetabolized parent compound and/or excretion of PETN via enterohepatic circulation, while PE was attributed to metabolic breakdown of PETN by intestinal flora and/or excretion of PETN via enterohepatic circulation (Davidson et al., 1971, 1970). The renal excretion of primary metabolites PEMN and PE in humans was first order, with half-lives of 7.1 hours following a 20-mg dose and 8.3 hours following a 40-mg dose (Davidson et al., 1971). In rats or mice, 36% of the administered oral dose was excreted within 24 hours in the urine, with 60% of the administered dose recovered after 4 days; 10% of the administered dose was recovered in rat feces (Litchfield, 1971). The primary urinary metabolites were PEMN and PE in rats and PE in mice, and the primary fecal metabolite was PE (NTP, 1989; Litchfield, 1971). In dogs, 88% of the administered oral dose was excreted in urine, primarily as PEMN and PE, and 10% was excreted in feces, primarily as PE (DiCarlo et al., 1969).

Table 5 Excretion of PETN and Metabolites in Humans Following a Single Oral Exposure

Compound Excreted | 20 mg^a^ | | 40 mg^b^
Compound Excreted | Urine | Feces | Urine | Feces
Percent of administered dose recovered (as radioactivity) within 48 h (urine) or 48−72 h (feces) | 60.3 ± 3.6 | 31.5 ± 4.8 | 49.8 | 41.2
Relative quantities (%) of parent compound and metabolites:
PETN | None to trace^c^ | 26.7 ± 13.4 | None | 45
PETriN | None | 0.4 ± 0.8 | None | None
PEDN | 0.6 ± 0.4 | 0.9 ± 1.5 | 1 | 2
PEMN | 51.4 ± 10.3 | 5.9 ± 3.5 | 74 | 2
PE | 48.1 ± 10.4 | 66.3 ± 14.6 | 25 | 51

a Davidson et al. (1970); data presented as mean ± SD, as reported by the study authors (percent excreted in urine and feces) or as calculated for this review based on individual subject data (relative quantities).

b Davidson et al. (1971); data presented as mean, as reported by the study authors (percent of administered dose recovered in urine and feces) or approximate mean (relative percent quantities of parent compound and metabolites; estimated from graphically presented data).

c PETN detected in trace amounts in the urine of one subject.

PE = pentaerythritol; PEDN = pentaerythritol dinitrate; PEMN = pentaerythritol mononitrate; PETN = pentaerythritol tetranitrate; PETriN = pentaerythritol trinitrate; SD = standard deviation.

### 2.3.4 Mode-of-Action/Mechanistic Studies

The therapeutic vasodilatory action of organic nitrates, including PETN, are attributed to their active intermediate, NO [reviewed by Daiber and Münzel (2015); Münzel et al. (2013); Kosmicki (2009); Daiber et al. (2008); Bode-Böger and Kojda (2005); Murad (1990)]. As discussed in the “Metabolism” section above, NO is released during PETN metabolism. Free NO is transported into the nucleus of vascular smooth muscle cells where it initiates the NO/cGMP intracellular signaling pathway, ultimately leading to smooth muscle relaxation [reviewed by Daiber and Münzel (2015); Münzel et al. (2013); Münzel and Gori (2013); Klemenska and Beresewicz (2009); Daiber et al. (2008); Murad (1990)]. However, the mechanisms underlying cerebral vasodilation (leading to the primary toxicologically relevant side effect of headaches) seem to be different from those identified for coronary vasodilation (therapeutic goal). As reviewed by Bode-Böger and Kojda (2005), the 100-fold decrease in the degree of vasodilation in cerebral arteries versus coronary arteries, in response to organic nitrate therapy, along with the cessation of headache after the first few days of therapy, supports the hypothesis that cerebral vasodilation occurs via a different pathway than coronary vasodilation. Evidence suggests that cerebral arteries may lack enzymes required for bioactivation of nitrates to NO. One proposed alternate mechanism for cerebral vasodilation in the absence of metabolism-generated NO is activation of the NO/cGMP pathway subsequent to direct activation of sensory nerve fibers by organic nitrates, triggering a release of calcitonin gene-related peptide.

Long-term organic nitrate use is generally associated with nitrate tolerance, endothelial dysfunction, sympathetic activation, and a potential increase in risk for ischemic episodes. PETN, however, is unique among the long-acting nitrovasodilators because chronic use is not associated with these effects. Long-acting in this instance refers to the action of the drug compared with NTG, not to the extended-release formulation of PETN, which is a separate issue. The mechanisms of nitrate tolerance have been extensively researched, and a summary of available data is presented below based on the following reviews: Bai et al. (2018); Opelt et al. (2018); Steven et al. (2017); Daiber and Münzel (2015); Münzel et al. (2013); Münzel and Gori (2013); Rutherford and Struthers (2013); Daiber et al. (2012); Daiber and Münzel (2010); Daiber et al. (2009); Klemenska and Beresewicz (2009); Kosmicki (2009); Daiber et al. (2008); Daiber et al. (2004). There are several potential mechanisms for nitrate tolerance and endothelial dysfunction following extended nitrate therapy, such as with NTG. Release of NO from PETN by ALDH-2 results in oxidation of the enzyme at the reactive cysteine C302, which requires an endogenous reductant for reactivation, which can be depleted, leading to the formation of reactive oxygen species (ROS). ROS generation and the subsequent formation of superoxide or peroxynitrite, can lead to reversible or irreversible inactivation of ALDH-2, resulting in reduced NO generation and a decreased therapeutic effect following nitrate administration. Additionally, peroxynitrite can cause uncoupling of endothelial NOS, leading to endothelial dysfunction. An additional mechanism of endothelial dysfunction and nitrate resistance may be through interaction of nitrates with the expression of prostaglandin I2 (PGI2) synthase. Nitrate donors induce the expression of miR-199 (a micro-RNA), which targets the PGI2 synthase messenger RNA (mRNA), lowering PGI2 levels and blocking vasodilation through that mechanism (Bai et al., 2018). However, neither PETN nor its metabolite PETriN affects the nitrate esterase activity of ALDH-2 or elicits ROS formation in isolated arteries or mitochondria. Furthermore, PETN exhibits intrinsic antioxidant properties due to the redox potential of its dinitrate metabolite and induction of protective genes, both in vitro and in vivo, including heme-oxygenase (HO-1) and ferritin (HO-1 mediates the conversion of heme into bilirubin, one of the strongest antioxidants in the body, and ferritin chelates iron, which suppresses hydroxyl radical formation). These antioxidant actions of PETN may explain the lack of nitrate tolerance or endothelial dysfunction following PETN therapy.

1 Single doses of 20 or 40 mg or placebo (randomized) were administered daily over a 5-day period (two treatment days, three placebo days), but blood pressure measurements were taken immediately after each dose.