# 1 INTRODUCTION

Pentaerythritol tetranitrate (PETN), CASRN 78-11-5, belongs to the class of compounds known as organic nitrates. It is used mainly as a demolition explosive and in the manufacture of detonating fuses and blasting caps (O’Neil, 2013; Lewis, 2007). Commercial PETN is usually mixed with plasticized nitrocellulose or synthetic rubber because PETN in its pure form is too sensitive to friction and impact (NCBI, 2021). PETN is one of the most powerful explosives known, and along with cyclotrimethylenetrinitramine (RDX), it is the main ingredient in Semtex, a plastic explosive. Additionally, PETN is one of a number of organic nitrates (e.g., nitroglycerin [NTG]) used therapeutically as coronary vasodilators in the treatment of cardiovascular conditions (angina pectoris, acute myocardial infarction, congestive heart failure). However, PETN was removed from most markets as a treatment option in the early 1990s, with the notable exception of Eastern Europe, because clear evidence of its efficacy was lacking [for recent reviews, see Daiber and Münzel (2015); Münzel et al. (2013); Münzel and Gori (2013); O’Neil (2013); Rutherford and Struthers (2013); Daiber et al. (2012); Daiber and Münzel (2010); Daiber et al. (2009); Gori and Daiber (2009); Kosmicki (2009); Bode-Böger and Kojda (2005)]. Its use (or consideration of use) in western countries has re-emerged, and clinical studies continue to re-evaluate its efficacy as a treatment for certain cardiovascular disease conditions (Daiber and Münzel, 2015; Rutherford and Struthers, 2013; Kalidindi et al., 2012; Gori and Daiber, 2009; Bode-Böger and Kojda, 2005). PETN is listed on U.S. EPA’s Toxic Substances Control Act’s (TSCA) public inventory (U.S. EPA, 2020b), and it is registered with Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (ECHA, 2018). PETN is subject to the Section 4 Test Rule (U.S. EPA, 2018b) and Section 12(b) Export Notifications (U.S. EPA, 2016) under TSCA. It is also listed on the 2015 Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) Substance Priority List (ATSDR, 2016).

Commercial PETN is produced by the continuous nitration of pentaerythritol. In this process, pentaerythritol and nitric acid are fed into a reaction where PETN precipitates, and is then isolated by dilution with water and filtration (NCBI, 2021). The empirical formula for PETN is C_5_H_8_N_4_O_12_, and its structure is shown in Figure 1. Table 1 summarizes its physicochemical properties. PETN is a white crystalline solid at room temperature and is extremely explosive, especially when dry, detonating at around 210°C (NOAA, 2016). PETN’s low vapor pressure and Henry’s law constant indicate that it is not expected to volatilize from either dry or moist surfaces. If PETN did partition to the atmosphere, its vapor pressure indicates that it would exist there in both the vapor and particulate phases. The estimated half-life of vapor-phase PETN in air by reaction with photochemically produced hydroxyl radicals is 6.6 days. The low water solubility and high soil adsorption coefficient for PETN indicate that it will have low mobility in soil and is not expected to leach to groundwater or undergo runoff after a rain event. Based on tests using microbial cultures isolated from river water and sewage sludge, PETN may undergo some degree of biodegradation in the environment (NCBI, 2021).

Figure 1 Pentaerythritol Tetranitrate (CASRN 78-11-5) Structure

This is the beginning of the long description for Figure 1. Figure 1 is titled Pentaerythritol Tetranitrate (C A S Registry Number 7 8 dash 1 1 dash 5) Structure. The empirical formula for pentaerythritol tetranitrate (or P E T N) is C 5 H 8 N 4 O 12. This is the end of the long description for Figure 1.

Table 1 Physicochemical Properties of PETN (CASRN 78-11-5)

Property (unit) | Value^a^
Physical state | Solid
Boiling point (°C) | 205−215 (explodes)^b^
Melting point (°C) | 141
Density (g/cm^3^ at 25°C) | 1.73 (predicted average)
Vapor pressure (mm Hg at 25°C) | 5.45 × 10^−9^
pH (unitless) | NA
pKa (unitless) | NA
Solubility in water (mol/L at 25°C) | 1.36 × 10^−4^
Octanol-water partition coefficient (log K_ow_) | 3.03 (predicted average)
Henry’s law constant (atm-m^3^/mol at 25°C) | 8.43 × 10^−7^ (predicted average)
Soil adsorption coefficient K_oc_ (L/kg) | 120 (predicted average)
Atmospheric OH rate constant (cm^3^/molecule-sec at 25°C) | 5.69 × 10^−13^ (predicted average)
Atmospheric half-life (d) | 6.6 (estimated)^c^
Relative vapor density (air = 1) | NA
Molecular weight (g/mol) | 316
Flash point (°C) | 170 (predicted average)

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard (PETN, CASRN 78-11-5. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID2023430. Accessed May 4, 2021). All values are experimental averages unless otherwise noted.

b NCBI (2021).

c U.S. EPA (2012b).

NA = not applicable; PETN = pentaerythritol tetranitrate.

A previous 2010 PPRTV assessment, which this document supersedes, was available for PETN from the U.S. EPA; no toxicity values are available from other agencies/organizations (see Table 2).

Table 2 Summary of Available Toxicity Values for PETN (CASRN 78-11-5)

Source (parameter)^a,^ ^b^ | Value | Notes | Reference^c^
Noncancer
PPRTV (p-RfD) | 2 × 10^−3^ mg/kg-d | Value is for both the subchronic and chronic p-RfDs | U.S. EPA (2010) (archived in 2021)
IRIS | NV | NA | U.S. EPA (2020a)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018a)
ATSDR | NV | NA | ATSDR (2018)
IPCS | NV | NA | IPCS (2020)
CalEPA | NV | NA | CalEPA (2019)
OSHA | NV | NA | OSHA (2020a); OSHA (2020b)
NIOSH | NV | NA | NIOSH (2021)
ACGIH | NV | NA | ACGIH (2020) ^d^
Cancer
PPRTV (p-OSF) | 4 × 10^−3^ (mg/kg-d)^−1^ | Screening p-OSF | U.S. EPA (2010) (archived in 2021)
IRIS | NV | NA | U.S. EPA (2020a)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018a)
NTP | NV | NA | NTP (2016)
IARC | NV | NA | IARC (2018)
CalEPA | NV | NA | CalEPA (2019)
ACGIH | NV | NA | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PPRTV = provisional peer-reviewed toxicity value.

b Parameters: p-OSF = provisional oral slope factor; p-RfD = provisional reference dose.

c Reference date is the publication date for the database and not the date the source was accessed.

d An ACGIH value for pentaerythritol is available; however, the tetranitrate form (PETN) is expected to have sufficiently different solubility (and other ADME parameters) making the applicability of this value unclear.

ADME = absorption, distribution, metabolism, excretion; NA = not applicable; NV = not available; PETN = pentaerythritol tetranitrate.

Literature searches were conducted in January 2016 and updated most recently in April 2021 for studies relevant to the derivation of provisional toxicity values for PETN (CASRN 78-11-5). Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE (including TSCATS1), and Web of Science. The following databases were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), Japan Existing Chemical Data Base (JECDB), European Chemicals Agency (ECHA), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).