# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Amsterdam, EA; Lee, G; Awan, NA; Low, R; Mason, DT. (1980). Effects of oral pentaerythritol tetranitrate in cardiac failure and angina pectoris. Assessment by hemodynamic measurement and exercise capacity. La Nouvelle presse médicale 9: 2443–2446.7422533
ATSDR (Agency for Toxic Substances and Disease Registry). (2016). The priority list of hazardous substances that will be the subject of toxicological profiles [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/spl/
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Minimal risk levels (MRLs). June 2018. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR).
Aubert, A; Nyberg, G; Slaastad, R; Tjeldflaat, L. (1970). Prophylactic treatment of angina pectoris. A double-blind cross-over comparison of alprenolol and pentanitrol. Br Med J 1: 203–206. 10.1136/bmj.1.5690.203 4391702
Aviado, DM; Kishimoto, T; Kneidinger, HJ. (1969). Bronchopulmonary effects of pentaerythrityl tetranitrate and isoproterenol. J Pharmacol Exp Ther 165: 274–285.5763062
Bai, YP; Zhang, JX; Sun, Q; Zhou, JP; Luo, JM; He, LF; Lin, XC; Zhu, LP; Wu, WZ; Wang, ZY; Zhang, GG. (2018). Induction of microRNA-199 by nitric oxide in endothelial cells is required for nitrovasodilator resistance via targeting of prostaglandin I2 synthase. Circulation 138: 397–411. 10.1161/CIRCULATIONAHA.117.029206 29431644
Banerjee, S; Mukherjee, AK; Halder, AK. (1970). Pentaerythritol tetranitrate sustained-release tablets: Relation of in vitro release of the drug to blood pressure changes after administration of anesthetized cats. J Pharm Sci 59: 273–274. 10.1002/jps.2600590233 5411356
Bassenge, E; Stalleicken, D; Fink, B. (1996). Non-intermittent long-term administration of pentaerithrityl-tetranitrate results in unexpected, tolerance-devoid coronary- and venodilation. In S Moncada; J Stamler; S Gross; EA Higgs (Eds.), Biology of Nitric Oxide, Part 5 (pp. 193–193). London, UK: Portland Press.
Bender, AD; Sullivan, FJ; Horvath, SM. (1963). Effects of continued pentaerythritol tetranitrate administration on myocardial circulation and metabolism. Experientia 19: 254–256.13967330
Bode-Böger, SM; Kojda, G. (2005). Organic nitrates in cardiovascular disease [Review]. Cell Mol Biol (Noisy-le-grand) 51: 307–320. 10.1170/T632 16191399
Bohm, C; Haustein, KO. (1998). Effect of pentaerithrityl tetranitrate on parameters of the microcirculation. Int J Clin Pharmacol Ther 36: 398–402.9707356
Bowkalow, S; Schleussner, E; Kähler, C; Schneider, U; Lehmann, T; Groten, T. (2018). Pentaerythrityltetranitrate (PETN) improves utero- and feto-placental Doppler parameters in pregnancies with impaired utero-placental perfusion in mid-gestation - a secondary analysis of the PETN-pilot trial. J Perinat Med 46: 1004–1009. 10.1515/jpm-2017-0238 29272253
Bucher, JR; Huff, J; Haseman, JK; Eustis, SL; Lilja, HS; Murthy, AS. (1990). No evidence of toxicity or carcinogenicity of pentaerythritol tetranitrate given in the diet to F344 rats and B6C3F1 mice for up to two years. J Appl Toxicol 10: 353–357. 10.1002/jat.2550100508 2254587
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
Cass, LJ; Cohen, JD. (1961). The correlation of pain relief with blood nitrate levels in angina pectoris when treated with pentaerythritol tetranitrate. Curr Ther Res 3: 23–27.13691313
Commarato, MA; Winbury, MM; Kaplan, HR. (1973). Glyceryl trinitrate and pentrinitrol (pentaerythritol trinitrate): Comparative cardiovascular effects in dog, cat and rat by different routes of administration. J Pharmacol Exp Ther 187: 300–307.4201273
Dagenais, GR; Mason, RE; Friesinger, GC; Wender, C; Ross, RS. (1969). Exercise tolerance in patients with angina pectoris: Daily variation and effect of pentaerythritol tetranitrate. Johns Hopkins Med J 125: 301–311.4905736
Daiber, A; Münzel, T. (2010). Characterization of the antioxidant properties of pentaerithrityl tetranitrate (PETN)-induction of the intrinsic antioxidative system heme oxygenase-1 (HO-1). In Advanced protocols in oxidative stress II, methods in molecular biology. New York, NY: Humana Press. 10.1007/978-1-60761-411-1_22
Daiber, A; Münzel, T. (2015). Organic nitrate therapy, nitrate tolerance, and nitrate-induced endothelial dysfunction: Emphasis on redox biology and oxidative stress. Antioxid Redox Signal 23: 899–942. 10.1089/ars.2015.6376 26261901
Daiber, A; Oelze, M; Coldewey, M; Bachschmid, M; Wenzel, P; Sydow, K; Wendt, M; Kleschyov, AL; Stalleicken, D; Ullrich, V; Mülsch, A; Münzel, T. (2004). Oxidative stress and mitochondrial aldehyde dehydrogenase activity: A comparison of pentaerythritol tetranitrate with other organic nitrates. Mol Pharmacol 66: 1372–1382. 10.1124/mol.104.002600 15331769
Daiber, A; Oelze, M; Wenzel, P; Bollmann, F; Pautz, A; Kleinert, H. (2012). Heme oxygenase-1 induction and organic nitrate therapy: Beneficial effects on endothelial dysfunction, nitrate tolerance, and vascular oxidative stress. Int J Hypertens 2012: 842632. 10.1155/2012/842632 22506100
Daiber, A; Oelze, M; Wenzel, P; Wickramanayake, JM; Schuhmacher, S; Jansen, T; Lackner, KJ; Torzewski, M; Münzel, T. (2009). Nitrate tolerance as a model of vascular dysfunction: Roles for mitochondrial aldehyde dehydrogenase and mitochondrial oxidative stress [Review]. Pharmacol Rep 61: 33–48. 10.1016/S1734-1140(09)70005-2 19307691
Daiber, A; Wenzel, P; Oelze, M; Münzel, T. (2008). New insights into bioactivation of organic nitrates, nitrate tolerance and cross-tolerance [Review]. Clin Res Cardiol 97: 12–20. 10.1007/s00392-007-0588-7 17938848
Davidson, IW; Miller, HS; DiCarlo, FJ. (1970). Absorption, excretion and metabolism of pentaerythritol tetranitrate by humans. J Pharmacol Exp Ther 175: 42–50.5471451
Davidson, IW; Miller, HS; DiCarlo, FJ. (1971). Pharmacodynamics and biotransformation of pentaerythritol tetranitrate in man. J Pharm Sci 60: 274–277. 10.1002/jps.2600600226 5572454
DiCarlo, FJ; Coutinho, CB; Crew, MC. (1967). Sites of absorption of pentaerythritol tetranitrate. Arch Int Pharmacodyn Ther 167: 163–170.6035093
DiCarlo, FJ; Melgar, MD; Haynes, LJ; Gala, RL; Crew, MC. (1969). Metabolism of pentaerythritol trinitrate and pentaerythritol by dogs. J Pharmacol Exp Ther 168: 235–239.5803306
Donahue, DD. (1944). Chronic toxic manifestations of PETN (pp. 30–39). (U.S. Public Health Bulletin No. 282). Washington, DC: Federal Security Agency, U.S. Public Health Service.
Dovinová, I; Cacányiová, S; Fáberová, V; Kristek, F. (2009). The effect of an NO donor, pentaerythrityl tetranitrate, on biochemical, functional, and morphological attributes of cardiovascular system of spontaneously hypertensive rats. Gen Physiol Biophys 28: 86–93. 10.4149/gpb_2009_01_86 19390141
Dragoni, S; Gori, T; Lisi, M; Di Stolfo, G; Pautz, A; Kleinert, H; Parker, JD. (2007). Pentaerythrityl tetranitrate and nitroglycerin, but not isosorbide mononitrate, prevent endothelial dysfunction induced by ischemia and reperfusion. Arterioscler Thromb Vasc Biol 27: 1955–1959. 10.1161/ATVBAHA.107.149278 17641250
ECHA (European Chemicals Agency). (2018). Registered Substances: Helsinki, Finland. Retrieved from http://echa.europa.eu/web/guest/information-on-chemicals/registered-substances
Edson, JN; Younger, D; Dipillo, F; Hoffman, I; Yarvis, M. (1961). A comparison of the effectiveness of pentaerythritol tetranitrate with pentaerythritol tetranitrate and meprobamate in angina pectoris. Am J Med Sci 241: 83–88.13725758
Fife, R; Howitt, G; Stevenson, J. (1958). Trial of drugs for angina of effort: The oral use of pentaerythritol tetranitrate, including a comparison with aminophylline and dihydroxypropyltheophylline. Scott Med J 3: 15–20. 10.1177/003693305800300102 13506598
Fink, B; Bassenge, E. (1997). Unexpected, tolerance-devoid vasomotor and platelet actions of pentaerythrityl tetranitrate. J Cardiovasc Pharmacol 30: 831–836. 10.1097/00005344-199712000-00020 9436825
Gerová, M; Kristek, F; Cacányiová, S; Cebová, M. (2005). Acetylcholine and bradykinin enhance hypotension and affect the function of remodeled conduit arteries in SHR and SHR treated with nitric oxide donors. Braz J Med Biol Res 38: 959–966. 10.1590/S0100-879X2005000600019 15933791
Giles, TD; Iteld, BJ; Quiroz, AC; Mautner, RK. (1981). The prolonged effect of pentaerythritol tetranitrate on exercise capacity in stable effort angina pectoris. Chest 80: 142–145. 10.1378/chest.80.2.142 7018846
Gori, T; Al-Hesayen, A; Jolliffe, C; Parker, JD. (2003). Comparison of the effects of pentaerythritol tetranitrate and nitroglycerin on endothelium-dependent vasorelaxation in humans. Eur Heart J 24: 318–318.
Gori, T; Daiber, A. (2009). Non-hemodynamic effects of organic nitrates and the distinctive characteristics of pentaerithrityl tetranitrate [Review]. Am J Cardiovasc Drugs 9: 7–15. 10.1007/BF03256591 19178128
Hacker, A; Müller, S; Meyer, W; Kojda, G. (2001). The nitric oxide donor pentaerythritol tetranitrate can preserve endothelial function in established atherosclerosis. Br J Pharmacol 132: 1707–1714. 10.1038/sj.bjp.0704021 11309242
Hedges, RN, Jr.; Gordon, WZ. (1965). A spectral analysis of coronary heart disease. Correlation of results of therapy using a long-acting nitrate compound. Angiology 16: 728–738. 10.1177/000331976501601202 5842923
Henstridge, DC; Duffy, SJ; Formosa, MF; Ahimastos, AA; Thompson, BR; Kingwell, BA. (2009). Oral nitrate therapy does not affect glucose metabolism in healthy men. Clin Exp Pharmacol Physiol 36: 1086–1092. 10.1111/j.1440-1681.2009.05195.x 19413595
IARC (International Agency for Research on Cancer). (2018). IARC monographs on the evaluation of carcinogenic risk to humans. http://monographs.iarc.fr/ENG/Monographs/PDFs/index.php
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Jurt, U; Gori, T; Ravandi, A; Babaei, S; Zeman, P; Parker, JD. (2001). Differential effects of pentaerythritol tetranitrate and nitroglycerin on the development of tolerance and evidence of lipid peroxidation: A human in vivo study. J Am Coll Cardiol 38: 854–859. 10.1016/S0735-1097(01)01414-0 11527645
Kalidindi, M; Velauthar, L; Khan, K; Aquilina, J. (2012). The role of nitrates in the prevention of preeclampsia: An update [Review]. Curr Opin Obstet Gynecol 24: 361–367. 10.1097/GCO.0b013e32835a31de 23108288
Klemenska, E; Beresewicz, A. (2009). Bioactivation of organic nitrates and the mechanism of nitrate tolerance [Review]. Cardiol J 16: 11–19.19130411
Kojda, G; Hacker, A; Noack, E. (1998). Effects of nonintermittent treatment of rabbits with pentaerythritol tetranitrate on vascular reactivity and superoxide production. Eur J Pharmacol 355: 23–31. 10.1016/S0014-2999(98)00460-9 9754935
Kojda, G; Noack, E. (1995). Effects of pentaerythrityl-tetranitrate and isosorbide-5-mononitrate in experimental atherosclerosis. In K Schrör; CR Pace-Asciak (Eds.), Mediators in the cardiovascular system : regional ischemia (pp. 201–206). Boston. MA: Birkhäuser Verlag.
Kojda, G; Stein, D; Kottenberg, E; Schnaith, EM; Noack, E. (1995). In vivo effects of pentaerythrityl-tetranitrate and isosorbide-5-mononitrate on the development of atherosclerosis and endothelial dysfunction in cholesterol-fed rabbits. J Cardiovasc Pharmacol 25: 763–773. 10.1097/00005344-199505000-00012 7543171
Kosmicki, MA. (2009). Long-term use of short- and long-acting nitrates in stable angina pectoris [Review]. Curr Clin Pharmacol 4: 132–141. 10.2174/157488409788185016 19442078
Kristek, F. (2000). Pentaerythrityl tetranitrate attenuates structural changes in conduit arteries evoked by long-term NO-synthase inhibition. Br J Pharmacol 130: 450–456. 10.1038/sj.bjp.0703307 10807685
Kristek, F; Fáberová, V; Varga, I. (2003). Long-term effect of molsidomine and pentaerythrityl tetranitrate on cardiovascular system of spontaneously hypertensive rats. Physiol Res 52: 709–717.14640892
Lewis, R. (2007). Pentaerythritol tetranitrate (PETN). In Hawley’s condensed chemical dictionary. New York, NY: John Wiley & Sons. 10.1021/jp0617930
Litchfield, MH. (1971). Aspects of nitrate ester metabolism [Review]. J Pharm Sci 60: 1599–1607.5002526
Mortelmans, K; Haworth, S; Lawlor, T; Speck, W; Tainer, B; Zeiger, E. (1986). Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8: 1–119. 10.1002/em.2860080702
Mullenheim, J; Muller, S; Laber, U; Thamer, V; Meyer, W; Bassenge, E; Fink, B; Kojda, G. (2001). The effect of high-dose pentaerythritol tetranitrate on the development of nitrate tolerance in rabbits. Naunyn-Schmiedebergs Arch Pharmacol 364: 269–275. 10.1007/s002100100464 11521170
Münzel, T; Daiber, A; Gori, T. (2013). More answers to the still unresolved question of nitrate tolerance [Review]. Eur Heart J 34: 2666–2673. 10.1093/eurheartj/eht249 23864131
Münzel, T; Gori, T. (2013). Nitrate therapy and nitrate tolerance in patients with coronary artery disease. Curr Opin Pharmacol 13: 251–259. 10.1016/j.coph.2012.12.008 23352691
Münzel, T; Meinertz, T; Tebbe, U; Schneider, HT; Stalleicken, D; Wargenau, M; Gori, T; Klingmann, I. (2014). Efficacy of the long-acting nitro vasodilator pentaerithrityl tetranitrate in patients with chronic stable angina pectoris receiving anti-anginal background therapy with beta-blockers: A 12-week, randomized, double-blind, placebo-controlled trial. Eur Heart J 35: 895–902. 10.1093/eurheartj/eht384 24071762
Murad, F. (1990). Drugs used for the treatment of angina: Organic nitrates, calcium-channel blockers, and β-adrenergic antagonists. In AG Gilman; TH Rall; AS Nies; P Taylor (Eds.), The pharmacological basis of therapeutics (8th ed., pp. 764–783). New York, NY: Pergamon Press.
NCBI (National Center for Biotechnology Information). (2021). PubChem annotation record for pentaerythritol tetranitrate, source: Hazardous Substances Data Bank (HSDB) [Database]: PubChem. Retrieved from https://pubchem.ncbi.nlm.nih.gov/source/hsdb/6313
NIOSH (National Institute for Occupational Safety and Health). (2021). NIOSH pocket guide to chemical hazards: Index of chemical abstracts service registry numbers (CAS No.). Available online at http://www.cdc.gov/niosh/npg/npgdcas.html
NOAA (National Oceanic and Atmospheric Administration). (2016). Cameo Chemicals. Version 2.4.2. Pentaerythritol tetranitrate. CAS number 78-11-5 (Version 2.6). Silver Spring, MD. Retrieved from https://cameochemicals.noaa.gov/chemical/12283
NTP (National Toxicology Program). (1989). Toxicology and carcinogenesis studies of pentaerythritol tetranitrate with 80% D-lactose monohydrate (PETN, NF) in F344/N rats and B6C3F1 mice (feed studies). (NTP TR 365). Research Triangle Park, NC: U.S. Department of Health and Human Services; Public Health Service; National Institutes of Health. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr365.pdf
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
O’Neil, MJ. (2013). Pentaerythritol tetranitrate. In MJ O’Neill; PE Heckelman; PH Dobbelaar; KJ Roman; CM Kenney; LS Karaffa (Eds.), The Merck index (15th ed., pp. 94). Cambridge, UK: Royal Society of Chemistry.
Oelze, M; Kröller-Schön, S; Steven, S; Lubos, E; Doppler, C; Hausding, M; Tobias, S; Brochhausen, C; Li, H; Torzewski, M; Wenzel, P; Bachschmid, M; Lackner, KJ; Schulz, E; Münzel, T; Daiber, A. (2014). Glutathione peroxidase-1 deficiency potentiates dysregulatory modifications of endothelial nitric oxide synthase and vascular dysfunction in aging. Hypertension 63: 390–396. 10.1161/HYPERTENSIONAHA.113.01602 24296279
Opelt, M; Wölkart, G; Eroglu, E; Waldeck-Weiermair, M; Malli, R; Graier, WF; Kollau, A; Fassett, JT; Schrammel, A; Mayer, B; Gorren, ACF. (2018). Sustained formation of nitroglycerin-derived nitric oxide by aldehyde dehydrogenase-2 in vascular smooth muscle without added reductants: Implications for the development of nitrate tolerance. Mol Pharmacol 93: 335–343. 10.1124/mol.117.110783 29358221
OSHA (Occupational Safety & Health Administration). (2020a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2020b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992
Perlman, A. (1952). A study of the therapeutic action and toxicity of pentaerythritol tetranitrate. Angiology 3: 16–19. 10.1177/000331975200300102 14903605
Phillips, E. (1953). A comparison of peritrate and other organic nitrates in the treatment of angina pectoris. Ariz Med 10: 171–174.13041573
Plotz, M. (1960). The treatment of angina pectoris with a new prolonged action pentaerythritol tetranitrate. Am J Med Sci 239: 194–197.
Potocnjak, D; Barić-Rafaj, R; Lemo, N; Matijatko, V; Kis, I; Mrljak, V; Harapin, I. (2008). Poisoning of a dog with the explosive pentaerythrityl tetranitrate. J Small Anim Pract 49: 314–318. 10.1111/j.1748-5827.2008.00549.x 18482332
Predel, HG; Knigge, H; Prinz, U; Kramer, HJ; Stalleicken, D; Rost, RE. (1995). Exercise increases endothelin-1 plasma concentrations in patients with coronary artery disease: Modulatory role of LDL cholesterol and of pentaerithrityltetranitrate. J Cardiovasc Pharmacol 26 Suppl 3: S497–S501.8587457
Quinn, MJ, Jr.; Crouse, LC; McFarland, CA; LaFiandra, EM; Johnson, MS. (2009). Reproductive and developmental effects and physical and chemical properties of pentaerythritol tetranitrate (PETN) in the rat. Birth Defects Res B Dev Reprod Toxicol 86: 65–71. 10.1002/bdrb.20184 19197946
Roberts, JT. (1958). Continuous twenty-four hour vasodilation in the treatment of angina pectoris; time-disintegration capsules containing pentaerythritol tetranitrate reduced the severity and frequency of angina pectoris attacks. Conn Med 22: 813–815.13609182
Rosenberg, HN; Michelson, AL. (1955). The use of pentaerythritol tetranitrate in chronic coronary insufficiency. Am J Med Sci 230: 254–258.13248858
Rutherford, E; Struthers, AD. (2013). Pentaerythrityl tetranitrate (PETN): A better nitrate? [Comment]. Eur Heart J 40: e23–e25. 10.1093/eurheartj/eht403
Schelling, JL; Lasagna, L. (1967). A study of cross-tolerance to circulatory effects of organic nitrates. Clin Pharmacol Ther 8: 256–260. 10.1002/cpt196782256 4960470
Schleussner, E; Lehmann, T; Kähler, C; Schneider, U; Schlembach, D; Groten, T. (2014). Impact of the nitric oxide-donor pentaerythrityl-tetranitrate on perinatal outcome in risk pregnancies: A prospective, randomized, double-blinded trial. J Perinat Med 42: 507–514. 10.1515/jpm-2013-0212 24421214
Schnorbus, B; Schiewe, R; Ostad, MA; Medler, C; Wachtlin, D; Wenzel, P; Daiber, A; Münzel, T; Warnholtz, A. (2010). Effects of pentaerythritol tetranitrate on endothelial function in coronary artery disease: Results of the PENTA study. Clin Res Cardiol 99: 115–124. 10.1007/s00392-009-0096-z 19957087
Shah, PK; Shellock, FG; Berman, DS; Rubin, SA; Singh, BN; Swan, HJ. (1980). Sustained beneficial effects of oral pentaerythritol tetranitrate on ventricular function in chronic congestive heart failure. La Nouvelle presse médicale 9: 2447–2450.7422534
Shellock, FG; Shah, PK; Berman, DS; Rubin, SA; Singh, BN; Swan, HJ. (1980). Sustained benefits or oral pentaerythritol tetranitrate on ventricular function in chronic congestive heart failure. Clin Pharmacol Ther 28: 436–440. 10.1038/clpt.1980.185 7408403
Shrivastava, RK; Tallury, VK; Dayican, G; Shah, BK. (1983). Pentaerythritol tetranitrate (Peritrate) efficacy trial in patients with angina-pectoris. Curr Ther Res 33: 841–847.
Steven, S; Oelze, M; Brandt, M; Ullmann, E; Kröller-Schön, S; Heeren, T; Tran, LP; Daub, S; Dib, M; Stalleicken, D; Wenzel, P; Münzel, T; Daiber, A. (2017). Pentaerythritol tetranitrate in vivo treatment improves oxidative stress and vascular dysfunction by suppression of endothelin-1 signaling in monocrotaline-induced pulmonary hypertension. Oxid Med Cell Longev 2017: 4353462. 10.1155/2017/4353462 28337251
Sullivan, FJ; Bender, AD; Horvath, SM. (1964). Acute effects of pentaerythritol tetranitrate on various myocardial hemodynamic and metabolic parameters in the normal anesthetized dog. Arch Int Pharmacodyn Ther 147: 229–235.14116932
Torok, J; Kristek, F. (2002). Beneficial effect of pentaerythrityl tetranitrate on functional and morphological changes in the rat thoracic aorta evoked by long-term nitric oxide synthase inhibition. Vascul Pharmacol 38: 177–182. 10.1016/S1537-1891(02)00193-3 12402517
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA/600/6-87/008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2010). Provisional Peer Reviewed Toxicity Values for pentaerythritol tetranitrate (PETN) (CASRN 78-11-5) [EPA Report]. Cincinnati, OH.
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Exposure factors handbook: 2011 edition [EPA Report]. (EPA/600/R-090/052F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=236252
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA/100/R-11/0001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Benchmark dose technical guidance. (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11 [Computer Program]. Washington, DC. Retrieved from https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface
U.S. EPA (U.S. Environmental Protection Agency). (2016). Chemicals subject to TSCA Section 12(b) export notification requirements (current as of May 27, 2016) [EPA Report]. https://www.epa.gov/tsca-import-export-requirements/tsca-requirements-exporting-chemicals
U.S. EPA (U.S. Environmental Protection Agency). (2018a). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2018b). Sunset dates of chemicals subject to final TSCA section 4: Test requirements and related section 12(b) actions [Database]. Retrieved from https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/sunset-dates-chemicals-subject-final-tsca-section-4-test
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2020b). The Toxic Substances Control Act’s public inventory (TSCA inventory). Updated June 2020 [Database]. Washington, DC: U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention. Retrieved from https://www.epa.gov/tsca-inventory/how-access-tsca-inventory#download
von Oettingen, WF; Donahue, DD. (1944). Acute toxic manifestations of PETN. In Toxicity and potential dangers of penta-erythritol-tetranitrate (PETN). (U.S. Public Health Bulletin No. 282). Washington, DC: Federal Security Agency, U.S. Public Health Service.
Weber, W; Michaelis, K; Luckow, V; Kuntze, U; Stalleicken, D. (1995). Pharmacokinetics and bioavailability of pentaerithrityl tetranitrate and two of its metabolites. Arzneimittelforschung 45: 781–784.8573222
Whong, WZ; Speciner, ND; Edwards, GS. (1980). Mutagenic activity of tetryl, a nitroaromatic explosive, in three microbial test systems. Toxicol Lett 5: 11–17. 10.1016/0378-4274(80)90142-3 6445609
Wu, Z; Siuda, D; Xia, N; Reifenberg, G; Daiber, A; Münzel, T; Förstermann, U; Li, H. (2015). Maternal treatment of spontaneously hypertensive rats with pentaerythritol tetranitrate reduces blood pressure in female offspring. Hypertension 65: 232–237. 10.1161/HYPERTENSIONAHA.114.04416 25385760