# APPENDIX C BENCHMARK DOSE MODELING RESULTS

## MODEL-FITTING PROCEDURE FOR CANCER INCIDENCE DATA

The model-fitting procedure for dichotomous cancer incidence is as follows. The Multistage-Cancer model in the U.S. EPA’s Benchmark Dose Software (BMDS, Version 2.6) is fit to the incidence data using the extra risk option. The Multistage-Cancer model is run for all polynomial degrees up to n − 1 (where n is the number of dose groups including control). An adequate model fit is judged by three criteria: (1) goodness-of-fit p-value (p > 0.05), (2) visual inspection of the dose-response curve, and (3) scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). Among all of the models providing adequate fit to the data, the benchmark dose lower confidence limit/benchmark concentration lower confidence limit (BMDL/BMCL) for the model with the lowest Akaike’s information criterion (AIC) is selected as the point of departure (POD). In accordance with U.S. EPA (2012a) guidance, benchmark dose/benchmark concentration (BMD/BMC) and BMDL/BMCL values associated with an extra risk of 10% are calculated. A combined tumor analysis using the MS-Combo model is run for each tumor type individually and then combined. A combined tumor analysis is appropriate when tumors of different clonal origin are indicated.

## BMD MODELING OF CANCER ENDPOINTS

The incidence data for Zymbal gland tumors and thyroid gland tumors in female rats were modeled separately and those results are shown in Tables C-1 and C-2 and Figures C-1 and C-2. The incidence data for Zymbal gland adenoma or carcinoma in female rats exposed to dietary pentaerythritol tetranitrate (PETN) for 2 years were combined with thyroid gland adenoma or carcinoma (Bucher et al., 1990; NTP, 1989) and used for BMD modeling using an MS-Combo model.

### Increased Incidence of Zymbal Gland Adenoma or Carcinoma in Female Rats Exposed to PETN for 2 Years

The procedure outlined above was applied to the data for increased combined incidence of Zymbal gland adenoma or carcinoma in female rats exposed to dietary PETN for 2 years (Bucher et al., 1990; NTP, 1989) (see Table C-1). Table C-2 summarizes the BMD modeling results. All models provided adequate fit to the data, so the model with the lowest AIC was selected (Multistage-Cancer 1st-degree). Thus, the BMDL_10_ (human equivalent dose [HED]) of 27 mg/kg-day from this model is selected for this endpoint (see Figure C-1).

### Increased Incidence of Thyroid Gland Adenoma or Carcinoma in Female Rats Exposed to PETN for 2 Years

The procedure outlined above was applied to the data for increased incidence of thyroid gland adenoma or carcinoma in female rats exposed to dietary PETN for 2 years (Bucher et al., 1990; NTP, 1989) (see Table C-1). Table C-2 summarizes the BMD modeling results. All models provided adequate fit to the data, so the model with the lowest AIC was selected (Multistage-Cancer 2nd-degree). Thus, the BMDL_10_ (HED) of 40 mg/kg-day from this model is selected for this endpoint (see Figure C-2).

Table C-1 Combined Incidence of Zymbal Gland and Thyroid Gland Tumors in Female F344/N Rats Administered Dietary PETN for 2 Years^a^

| HED, mg/kg-d^b^
| 0 | 20 | 41.3
Sample size^c^ | 36/50 | 37/48 | 35/50
Zymbal gland incidence | 0 | 1 | 3
Thyroid gland incidence | 0 | 0 | 3

a Bucher et al. (1990); NTP (1989).

b Estimated daily animal doses were converted into HEDs based on the animal:human BW^1/4^ ratio (U.S. EPA, 2005) using study-specific TWA BWs for rats and 70 kg for humans (U.S. EPA, 2011c).

c Note that sample sizes in the Zymbal gland and thyroid gland tumor analyses are different (see Table A-1).

BW = body weight; HED = human equivalent dose; PETN = pentaerythritol tetranitrate; TWA = time-weighted average.

### Model Predictions for Zymbal Gland and Thyroid Gland Adenomas or Carcinomas in Female Rats Administered Dietary PETN for 2 Years

The procedure outlined above was applied to the data for incidence of Zymbal gland and thyroid gland adenomas or carcinomas in female rats (see Table C-1). The software converged on the Multistage-Cancer 1st-degree model for the Zymbal gland tumors and the Multistage-Cancer 2nd-degree model for thyroid tumors, which provided adequate fit (p > 0.05); thus, these were selected as the best-fitting models (see Table C-2). The BMDL_10_ (HED) values from these models are 27.0 and 39.7 mg/kg-day, respectively. Figures C-1 and C-2 show the model fit to the data. The MS-Combo model yields a BMDL_10_ (HED) value of 23 mg/kg-day, and the model output for the combined tumor analysis is shown in Table C-2.

Table C-2 BMD Model Results for Zymbal and Thyroid Gland Adenoma and Carcinoma in Female Rats Administered Dietary PETN for 2 Years^a^

Model | df | χ^2^ Goodness-of-Fit p-Value^b^ | Scaled Residual: Dose Nearest BMD^c^ | Scaled Residual: Control BMD^c^ | AIC | BMD_10_ mg/kg-d | BMDL_10_ mg/kg-d
Zymbal Gland Multistage-Cancer (1st-degree) ^d^ | 2 | 0.9224 | 0.236 | 0 | 31.84 | 55.6481 | 26.9849
Zymbal Gland Multistage-Cancer (2nd-degree) | 1 | 1 | 0 | 0 | 33.67 | 45.3659 | 27.5424
Thyroid Gland Multistage-Cancer (1st-degree) | 2 | 0.4859 | 0.679 | 0 | 27.0466 | 104.048 | 45.8064
Thyroid Gland Multistage-Cancer (2nd-degree) ^d^ | 2 | 0.7050 | 0.361 | 0 | 25.9494 | 59.8238 | 39.6929
Multitumor (MS-Combo) ^d^ | NA | NA | NA | NA | NA | 35.76216 | 22.59085

a Bucher et al. (1990); NTP (1989).

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals for dose group near BMD.

d Selected model. All models provided adequate fit to the data. BMDLs for models providing adequate fit were nearly identical, so the model with the lowest AIC was selected.

AIC = Akaike’s information criterion; BMD = benchmark dose; BMD_10_ = 10% benchmark dose; BMDL = benchmark dose lower confidence limit (subscripts denote BMR: i.e., 10 = exposure concentration associated with 10% extra risk); df = degree(s) of freedom; NA = not applicable; PETN = pentaerythritol tetranitrate.

Figure C-1 Multistage (1-Degree) Model for Incidence of Zymbal Gland Adenoma or Carcinoma in Female F344/N Rats Administered Dietary PETN for 2 Years (Bucher et al., 1990; NTP, 1989)

Text Output for Figure C-1:

====================================================================  
     Multistage Cancer Model. (Version: 1.10;  Date: 02/28/2013)  
     Input Data File: C:/Users/JKaiser/Desktop/BMDS240/Data/msc_zym_petn_Msc1-BMR10.(d)   
     Gnuplot Plotting File:  C:/Users/JKaiser/Desktop/BMDS240/Data/msc_zym_petn_Msc1-BMR10.plt 
                                               Wed Sep 13 12:19:57 2017 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Effect 
   Independent variable = Dose 
 
 Total number of observations = 3 
 Total number of records with missing values = 0 
 Total number of parameters in model = 2 
 Total number of specified parameters = 0 
 Degree of polynomial = 1 
 
 
 Maximum number of iterations = 500 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =            0 
                        Beta(1) =   0.00217791 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
           ( *** The model parameter(s)  -Background    
                 have been estimated at a boundary point, or have been specified by the user, 
                 and do not appear in the correlation matrix ) 
 
                Beta(1) 
 
   Beta(1)            1 
 
 
 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background                0            *                *                  * 
        Beta(1)       0.00189334            *                *                  * 
 
* - Indicates that this value is not calculated. 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -14.8351         3 
   Fitted model        -14.9202         1      0.170198      2          0.9184 
  Reduced model        -17.1083         1       4.54653      2           0.103 
 
           AIC:         31.8404 
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0000         0.000     0.000          36        0.000 
   20.0000     0.0372         1.375     1.000          37       -0.326 
   41.3000     0.0752         2.633     3.000          35        0.236 
 
 Chi^2 = 0.16      d.f. = 2        P-value = 0.9224 
 
   Benchmark Dose Computation 
 
Specified effect =            0.1 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        55.6481 
 
            BMDL =        26.9849 
 
            BMDU =        205.925 
 
Taken together, (26.9849, 205.925) is a 90     % two-sided confidence 
interval for the BMD 
 
Multistage Cancer Slope Factor =    0.00370577

Figure C-2 Multistage (2-Degree) Model for Incidence of Thyroid Gland Adenoma or Carcinoma in Female F344/N Rats Administered Dietary PETN for 2 Years (Bucher et al., 1990; NTP, 1989)

Text Output for Figure C-2:

 ====================================================================  
     Multistage Model. (Version: 3.4;  Date: 05/02/2014)  
     Input Data File: //AA.AD.EPA.GOV/ORD/CIN/USERS/MAIN/A-E/DPETERSE/Net MyDocuments/BMDS/BMDS2704/msc_PETN Thyroid Female_Opt.(d)   
     Gnuplot Plotting File:  //AA.AD.EPA.GOV/ORD/CIN/USERS/MAIN/A-E/DPETERSE/Net MyDocuments/BMDS/BMDS2704/msc_PETN Thyroid Female_Opt.plt 
                                               Wed Sep 04 15:32:35 2019 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1-beta2*dose^2)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Effect 
   Independent variable = Dose 
 
 Total number of observations = 3 
 Total number of records with missing values = 0 
 Total number of parameters in model = 3 
 Total number of specified parameters = 0 
 Degree of polynomial = 2 
 
 
 Maximum number of iterations = 500 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =            0 
                        Beta(1) =            0 
                        Beta(2) = 3.90286e-005 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
           ( *** The model parameter(s)  -Background    -Beta(1)    
                 have been estimated at a boundary point, or have been specified by the user, 
                 and do not appear in the correlation matrix ) 
 
                Beta(2) 
 
   Beta(2)            1 
 
 
 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background                0               NA 
        Beta(1)                0               NA 
        Beta(2)     2.94395e-005     1.69987e-005       -3.87732e-006        6.27563e-005 
 
NA - Indicates that this parameter has hit a bound 
     implied by some inequality constraint and thus 
     has no standard error. 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -11.3484         3 
   Fitted model        -11.9747         1       1.25261      2          0.5346 
  Reduced model        -14.6652         1       6.63362      2         0.03627 
 
           AIC:         25.9494 
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0000         0.000     0.000      50.000        0.000 
   20.0000     0.0117         0.562     0.000      48.000       -0.754 
   41.3000     0.0490         2.449     3.000      50.000        0.361 
 
 Chi^2 = 0.70      d.f. = 2        P-value = 0.7050 
 
 
   Benchmark Dose Computation 
 
Specified effect =            0.1 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        59.8238 
 
            BMDL =        39.6929 
 
            BMDU =        243.165 
 
Taken together, (39.6929, 243.165) is a 90     % two-sided confidence 
interval for the BMD 
 
Cancer Slope Factor =    0.00251934

Text Output for MS-Combo Model for Combined Incidence of Zymbal Gland Adenoma or Carcinoma and Thyroid Gland Adenoma or Carcinoma in Female F344/N Rats Administered Dietary PETN for 2 Years (Bucher et al., 1990; NTP, 1989):

====================================================================  
     MS_COMBO. (Version: 1.10;  Date: 01/29/2017)  
     Input Data File: C:\Users\dpeterse\OneDrive - Environmental Protection Agency (EPA)\Profile\Desktop\test.(d)   
     Gnuplot Plotting File:  C:\Users\dpeterse\OneDrive - Environmental Protection Agency (EPA)\Profile\Desktop\test.plt 
                                        Wed Sep 04 17:17:51 2019 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Effect 
   Independent variable = Dose 
   Data file name = PETNZybmalFemale.dax 
 
 Total number of observations = 3 
 Total number of records with missing values = 0 
 Total number of parameters in model = 2 
 Total number of specified parameters = 0 
 Degree of polynomial = 1 
 
 
 Maximum number of iterations = 500 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =            0 
                        Beta(1) =   0.00217791 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
           ( *** The model parameter(s)  -Background    
                 have been estimated at a boundary point, or have been specified by the user, 
                 and do not appear in the correlation matrix ) 
 
                Beta(1) 
 
   Beta(1)            1 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background                0            *                *                  * 
        Beta(1)       0.00189334            *                *                  * 
 
* - Indicates that this value is not calculated. 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -14.8351         3 
   Fitted model        -14.9202         1      0.170198      2          0.9184 
  Reduced model        -17.1083         1       4.54653      2           0.103 
 
           AIC:         31.8404 
 
 Log-likelihood Constant             12.397374590988454  
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0000         0.000     0.000      36.000        0.000 
   20.0000     0.0372         1.375     1.000      37.000       -0.326 
   41.3000     0.0752         2.633     3.000      35.000        0.236 
 
 Chi^2 = 0.16      d.f. = 2        P-value = 0.9224 
 
 
   Benchmark Dose Computation 
 
Specified effect =            0.1 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        55.6481 
 
            BMDL =        26.9849 
 
            BMDU =        205.925 
 
Taken together, (26.9849, 205.925) is a 90     % two-sided confidence 
interval for the BMD 
 
Multistage Cancer Slope Factor =    0.00370577 
 
 
 ====================================================================  
      MS_COMBO. (Version: 1.10;  Date: 01/29/2017)  
     Input Data File: C:\Users\dpeterse\OneDrive - Environmental Protection Agency (EPA)\Profile\Desktop\test.(d)   
     Gnuplot Plotting File:  C:\Users\dpeterse\OneDrive - Environmental Protection Agency (EPA)\Profile\Desktop\test.plt 
                                        Wed Sep 04 17:17:51 2019 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1-beta2*dose^2)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Effect 
   Independent variable = Dose 
   Data file name = PETNThyroidFemale.dax 
 
 Total number of observations = 3 
 Total number of records with missing values = 0 
 Total number of parameters in model = 3 
 Total number of specified parameters = 0 
 Degree of polynomial = 2 
 
 
 Maximum number of iterations = 500 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =            0 
                        Beta(1) =            0 
                        Beta(2) = 3.90286e-005 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
           ( *** The model parameter(s)  -Background    -Beta(1)    
                 have been estimated at a boundary point, or have been specified by the user, 
                 and do not appear in the correlation matrix ) 
 
                Beta(2) 
 
   Beta(2)            1 
 
 
 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background                0            *                *                  * 
        Beta(1)                0            *                *                  * 
        Beta(2)     2.94395e-005            *                *                  * 
 
* - Indicates that this value is not calculated. 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -11.3484         3 
   Fitted model        -11.9747         1       1.25261      2          0.5346 
  Reduced model        -14.6652         1       6.63362      2         0.03627 
 
           AIC:         25.9494 
 
 Log-likelihood Constant             9.8832848452188156  
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0000         0.000     0.000      50.000        0.000 
   20.0000     0.0117         0.562     0.000      48.000       -0.754 
   41.3000     0.0490         2.449     3.000      50.000        0.361 
 
 Chi^2 = 0.70      d.f. = 2        P-value = 0.7050 
 
 
   Benchmark Dose Computation 
 
Specified effect =            0.1 
 
Risk Type        =      Extra risk  
Confidence level =           0.95 
 
             BMD =        59.8238 
 
            BMDL =        39.6929 
 
            BMDU =        243.165 
 
Taken together, (39.6929, 243.165) is a 90     % two-sided confidence 
interval for the BMD 
 
Multistage Cancer Slope Factor =    0.00251934 
 
 
 
**** Start of combined BMD and BMDL Calculations.**** 
 
  Combined Log-Likelihood                     -26.894855234855342  
 
  Combined Log-likelihood Constant             22.280659436207269  
 
 
   Benchmark Dose Computation 
 
Specified effect =            0.1 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        35.7621 
 
            BMDL =        22.5908 
 
            BMDU =        61.8096 
 
Multistage Cancer Slope Factor =    0.00442657