# APPENDIX B DATA TABLES

Table B-1 Acute Clinical Studies Evaluating Subjective Complaints Following PETN Administration

Study/Type | Subjects | Duration and Dose^a^ | Results
Fife et al. (1958); Double-blind clinical trial, crossover design | Trial 1: 75 angina patients; 53 M/2 F;; Trial 2: 42 angina patients, subset of Trial 1, sex not reported.; Each subject received both placebo and PETN treatment (2 wk on, 2 wk off, with half receiving treatment each 2-wk period). | 2 wk;; Trial 1: 0, 2.6 mg/kg-d;; Trial 2: 0,; 1.3−2.6 mg/kg-d PETN, dose was 1.3 mg/kg-d for first week and; 2.6 mg/kg-d for second week of the second trial, if tolerated. | “Mild” side effects (headache, giddiness, palpitation, insomnia, GI symptoms):; Trial 1: 14/75 PETN, 12/75 placebo; p > 0.1;^b^; Trial 2: 7/42 PETN, 6/42 placebo; p > 0.1; “Moderate to severe” side effects (headache/nausea):; Trial 1: 8/75 PETN, 2/75 placebo; p = 0.1;; Trial 2: 5/42 PETN, 0/42 placebo; p = 0.06
Roberts (1958); Double-blind clinical trial, crossover design | 42 angina patients, 40 M/2 F.; Both standard PETN and time-release were used.; Each subject received a placebo and PETN treatment during the study period at 2-wk intervals; neither doctor nor patient knew what treatment was supplied at bimonthly visits. | 2-wk intervals over experimental period (up to 9 mo.); 0, 0.86, 1.7 mg/kg-d | Transient effects were reported in some subjects and disappeared after a few days; effects included headache or flushing (6/42), itching (2/42), and exacerbation of existing eczema (2/42). Incidence of side effects was not reported for the placebo period.
Amsterdam et al. (1980); Double-blind clinical trial, crossover design | 12 (10 M/2 F) heart failure patients; 8 of the subjects received both placebo and PETN treatment; time between treatment administration was determined by “return to baseline” hemodynamics. | Once; 0, 0.57 mg/kg | Qualitative: Side effects were evaluated but not reported.
Predel et al. (1995); Double-blind clinical trial | 5 healthy and 5 coronary artery disease (20 M/0 F) patients per group. | 3 d; 0, 4.3 mg/kg-d | Qualitative: No side effects reported.

a Doses in mg/kg-day were calculated using reported body-weight means (if available) or a reference human body weight of 70 kg (U.S. EPA, 2011c).

b All statistics in this table were performed for this review (two-tailed Fisher’s exact test).

F = female(s); GI = gastrointestinal; M = male(s); PETN = pentaerythritol tetranitrate.

Table B-2 Body Weight for F344/N Rats and B6C3F1 Mice Exposed to PETN in the Diet for 14 Days^a^

Parameter^b^ | Exposure, ppm PETN (mg/kg-d)^c^
Male rats | 0 | 620 (65.7) | 1,240 (129.0) | 2,500 (347.8) | 5,000 (674) | 10,000 (1,110)
Terminal body weight (g) | 208 ± 7 | 207 ± 5 (−0) | 213 ± 5 (+2) | 213 ± 7 (+2) | 209 ± 5 (+0) | 209 ± 7 (+0)
Body-weight gain (g) | 69 ± 8 | 74 ± 2 (+7) | 80 ± 1 (+16) | 81 ± 4 (+17) | 77 ± 2 (+12) | 77 ± 3 (+12)
Female rats | 0 | 620 (79.0) | 1,240 (168.0) | 2,500 (355.7) | 5,000 (635) | 10,000 (1,310)
Terminal body weight (g) | 145 ± 3 | 144 ± 2 (−1) | 145 ± 2 (0) | 147 ± 1 (+1) | 145 ± 2 (0) | 138 ± 1 (−5)
Body-weight gain (g) | 41 ± 2 | 37 ± 1 (−10) | 39 ± 2 (−5) | 41 ± 1 (0) | 38 ± 1 (−7) | 31 ± 1^d^ (−24)
Male mice | 0 | 620 (173) | 1,240 (308.7) | 2,500 (539.7) | 5,000 (1,380) | 10,000 (2,600)
Terminal body weight (g) | 25.6 ± 1 | 25.1 ± 1.1 (−2) | 25.6 ± 0.8 (0) | 26.1 ± 1 (+2) | 27.1 ± 1 (+6) | 25.9 ± 0.8 (+1)
Body-weight gain (g) | 2.7 ± 0.3 | 2.2 ± 0.4 (−19) | 3 ± 0.3 (+11) | 3.1 ± 0.5 (+15) | 4.3 ± 0.3 (+59) | 3.3 ± 0.2 (+22)
Female mice | 0 | 620 (187) | 1,240 (556.9) | 2,500 (703.1) | 5,000 (1,800) | 10,000 (2,530)
Terminal body weight (g) | 20.6 ± 0.4 | 20.2 ± 0.5 (−2) | 20.1 ± 0.4 (−2) | 20.1 ± 0.2 (−2) | 19.7 ± 0.4 (−4) | 18 ± 0.9^d^ (−13)
Body-weight gain (g) | 2.6 ± 0.1 | 2 ± 0.3 (−23) | 1.9 ± 0.2 (−27) | 1.8 ± 0.4 (−31) | 1.1 ± 0.4^d^ (−58) | 0.4 ± 0.7^d^ (−85)

a Bucher et al. (1990); NTP (1989).

b Data reported as mean ± SEM (% change compared with control) for 5 mice; % change control = [(treatment mean − control mean) ÷ control mean] × 100.

c Daily doses in mg/kg-day were calculated for this review based on reported body-weight and food-consumption data.

d Significantly different from control (p < 0.05), as calculated for this review (Student’s t-test).

PETN = pentaerythritol tetranitrate; SEM = standard error of the mean.

Table B-3 Body Weight and Relative Organ Weights in F344/N Rats Exposed to PETN in the Diet for 14 Weeks^a^

Parameter^b^ | Exposure, ppm PETN (mg/kg-d)^c^
Male | 0 | 620 (39.1) | 1,240 (88.04) | 2,500 (190) | 5,000 (330) | 10,000 (630)
Terminal body weight (g) | 339 ± 9 | 331 ± 8 (−2) | 335 ± 7 (−1) | 351 ± 6 (+4) | 336 ± 8 (−1) | 336 ± 6 (−1)
Body-weight gain (g) | 156 ± 6 | 147 ± 10 (−6) | 152 ± 6 (−3) | 168 ± 6 (+8) | 153 ± 5 (−2) | 153 ± 5 (−2)
Brain (mg/g BW) | 5.2 ± 0.15 [n = 6] | 5.5 ± 0.11 (+6) [n = 6] | 5.5 ± 0.12 (+6) [n = 6] | 5.1 ± 0.49 (−2) [n = 6] | 5.4 ± 0.53 (+4) [n = 6] | 5.6 ± 0.12 (+8) [n = 6]
Liver (mg/g BW) | 37 ± 0.88 | 30.6 ± 0.98^**^ (−17) | 32.5 ± 1.24^*^ (−12) | 32.9 ± 1.61 (−11) | 33.1 ± 0.9 (−11) | 32.7 ± 1.52 (−12)
Right kidney (mg/g BW) | 4.6 ± 0.55 | 4.5 ± 0.6 (−2) | 4.4 ± 0.54 (−4) | 4.6 ± 0.61 (0) | 4.5 ± 0.52 (−2) | 4.6 ± 0.55 (0)
Thymus (mg/g BW) | 1 ± 0.16 | 1 ± 0.29 (0) | 0.8 ± 0.1 (−20) | 1 ± 0.16 (0) | 0.7 ± 0.02 (−30) | 0.8 ± 0.12 (−20)
Heart (mg/g BW) | 2.7 ± 0.06 | 2.7 ± 0.08 (0) | 2.7 ± 0.08 (0) | 2.9 ± 0.25 (+7) | 2.7 ± 0.08 (0) | 2.6 ± 0.07 (−4)
Lung (mg/g BW) | 4.1 ± 0.12 [n = 5] | 3.7 ± 0.1 (−10) [n = 6] | 3.9 ± 0.2 (−5) [n = 6] | 3.8 ± 0.18 (−7) [n = 6] | 3.7 ± 0.1 (−10) [n = 5] | 3.9 ± 0.09 (−5) [n = 6]
Female | 0 | 620 (42.8) | 1,240 (85.56) | 2,500 (200) | 5,000 (370) | 10,000 (830)
Terminal body weight (g) | 215 ± 2 | 210 ± 3 (−2) | 211 ± 3 (−2) | 206 ± 4 (−4) | 203 ± 4^d^ (−6) | 201 ± 4^d^ (−7)
Body-weight gain (g) | 76 ± 3 | 70 ± 2 (−8) | 72 ± 1 (−5) | 67 ± 2^d^ (−12) | 63 ± 2^d^ (−17) | 62 ± 2^d^ (−18)
Brain (mg/g BW) | 8.3 ± 0.09 | 8.6 ± 0.15 (+4) | 8.7 ± 0.12 (+5) | 8.8 ± 0.13^*^ (+6) | 9 ± 0.13^**^ (+8) | 9 ± 0.19^**^ (+8)
Liver (mg/g BW) | 32.9 ± 0.41 | 32.5 ± 0.63 (−1) | 31.1 ± 0.7 (−5) | 32.3 ± 0.74 (−2) | 31.9 ± 0.85 (−3) | 33.1 ± 0.78 (+1)
Right kidney (mg/g BW) | 3.1 ± 0.05 | 3.1 ± 0.05 (0) | 3.1 ± 0.05 (0) | 3.2 ± 0.06 (+3) | 3.2 ± 0.05 (+3) | 3.3 ± 0.06^*^ (+6)
Thymus (mg/g BW) | 1.1 ± 0.1 | 1 ± 0.03 (−9) | 1.1 ± 0.02 (0) | 1 ± 0.04 (−9) | 1 ± 0.04 (−9) | 0.9 ± 0.05 (−18)
Heart (mg/g BW) | 2.8 ± 0.04 | 2.8 ± 0.05 (0) | 2.8 ± 0.08 (0) | 2.9 ± 0.06 (+4) | 2.9 ± 0.07 (+4) | 3 ± 0.06 (+7)
Lung (mg/g BW) | 4.8 ± 0.11 | 4.6 ± 0.08 (−4) | 4.7 ± 0.1 (−2) | 4.8 ± 0.08 (0) | 4.8 ± 0.11 (0) | 4.7 ± 0.12 (−2)

a Bucher et al. (1990); NTP (1989).

b Data reported as mean ± SEM (percent change compared with control) for 10 rats, unless otherwise noted; percent change control = [(treatment mean − control mean) ÷ control mean] × 100.

c Daily doses in mg/kg-day were calculated for this review based on daily food intake (in g/kg BW) reported by the study authors.

d Statistically significantly different from control (p < 0.05), as calculated for this review (Student’s t-test).

* Statistically significantly different from control (p < 0.05), as reported by the study authors.

** Statistically significantly different from control (p < 0.01), as reported by the study authors.

BW = body weight; PETN = pentaerythritol tetranitrate; SEM = standard error of the mean.

Table B-4 Body Weight and Relative Organ Weights in B6C3F1 Mice Exposed to PETN in the Diet for 13 Weeks^a^

Parameter^b^ | Exposure, ppm PETN (mg/kg-d)^c^
Male | 0 | 620 (109) | 1,240 (302.6) | 2,500 (362.5) | 5,000 (925) | 10,000 (2,140)
Terminal body weight (g) | 30.9 ± 0.3 | 32 ± 0.6 (+4) | 30 ± 0.8 (−3) | 32.7 ± 0.8 (+6) | 31.6 ± 0.6 (+2) | 31.1 ± 0.6 (+1)
Brain (mg/g BW) | 14.6 ± 0.34 | 14.5 ± 0.56 (−1) | 14.3 ± 0.4 (−2) | 14.1 ± 0.37 (−3) | 14.8 ± 0.34 (+1) | 15.2 ± 0.34 (+4)
Liver (mg/g BW) | 52.9 ± 1.01 | 55.1 ± 0.97 (+4) | 56.3 ± 1.13 (+6) | 53.7 ± 1.49 (+2) | 55.4 ± 2.13 (+5) | 52.3 ± 1.34 (−1)
Right kidney (mg/g BW) | 8.8 ± 0.27 | 8.9 ± 0.25 (+1) | 8.8 ± 0.38 (0) | 8.7 ± 0.21 (−1) | 8.4 ± 0.16 (−5) | 9.1 ± 0.21 (+3)
Thymus (mg/g BW) | 1.3 ± 0.13 | 1.2 ± 0.11 (−8) | 1.3 ± 0.26 (0) | 1.2 ± 0.17 (−8) | 1.2 ± 0.11 (−8) | 1.3 ± 0.24 (0)
Heart (mg/g BW) | 4.8 ± 0.15 | 4.8 ± 0.11 (0) [n = 9] | 4.8 ± 0.14 (0) | 4.5 ± 0.12 (−6) | 4.7 ± 0.15 (−2) | 4.8 ± 0.11 (0)
Lung (mg/g BW) | 5.9 ± 0.19 | 6.2 ± 0.3 (+5) | 6 ± 0.33 (+2) | 6 ± 0.38 (+2) | 6.1 ± 0.23 (+3) | 6.3 ± 0.25 (+7)
Female | 0 | 620 (172) | 1,240 (306.3) | 2,500 (632.5) | 5,000 (1,340) | 10,000 (3,120)
Terminal body weight (g) | 27.3 ± 0.6 | 29 ± 0.7 (+6) | 29.1 ± 0.7 (+7) | 27.4 ± 0.6 (+0.4) | 28.3 ± 0.7 (+4) | 27.7 ± 0.8 (+1)
Brain (mg/g BW) | 17.9 ± 0.35 | 17.4 ± 0.5 (−3) | 17.4 ± 0.41 (−3) | 17.7 ± 0.46 (−1) | 17.4 ± 0.46 (−3) | 18 ± 0.41 (+1)
Liver (mg/g BW) | 50.2 ± 0.71 | 51.7 ± 1.16 (+3) | 49.8 ± 0.94 (−1) | 51.7 ± 0.75 (+3) | 52.5 ± 1.1 (+5) | 53.8 ± 0.71^*^ (+7)
Right kidney (mg/g BW) | 6.4 ± 0.1 | 6.8 ± 0.21 (+6) | 6.3 ± 0.14 (−2) | 6.6 ± 0.11 (+3) | 6.7 ± 0.15 (+5) | 6.9 ± 0.12^*^ (+8)
Thymus (mg/g BW) | 1.8 ± 0.16 | 1.6 ± 0.12 (−11) | 1.8 ± 0.19 (0) | 1.8 ± 0.21 (0) | 1.8 ± 0.15 (0) | 2 ± 0.14 (+11)
Heart (mg/g BW) | 4.5 ± 0.13 | 4.3 ± 0.1 (−4) | 4.1 ± 0.1 (−9) | 4.4 ± 0.17 (−2) | 4.4 ± 0.15 (−2) | 4.5 ± 0.1 (0)
Lung (mg/g BW) | 7.2 ± 0.27 | 6.9 ± 0.24 (−4) | 6.3 ± 0.33 (−13) | 6.5 ± 0.31 (−10) | 6.6 ± 0.32 (−8) | 6.8 ± 0.28 (−6)

a Bucher et al. (1990); NTP (1989).

b Data reported as mean ± SEM (percent change compared with control) for 10 mice, unless otherwise noted; percent change control = [(treatment mean − control mean) ÷ control mean] × 100.

c Daily doses in mg/kg-day were calculated for this review based on daily food intake (in g/kg BW) reported by the study authors.

* The p-value was statistically significant at < 0.05.

BW = body weight; PETN = pentaerythritol tetranitrate; SEM = standard error of the mean.

Table B-5 Incidences of Zymbal Gland and Thyroid Gland Tumors in F344/N Rats Exposed to PETN in the Diet for 2 Years^a^

| | Exposure, ppm PETN (mg/kg-d)^b^
Male | | 0 | 5,000 (240) | 10,000 (490)
Zymbal gland | Hyperplasia | 0/49 (0%) | 1/45 (2%) | 0/41 (0%)
Zymbal gland | Adenoma | 0/49 (0%) | 1/45 (2%) | 0/41 (0%)
Zymbal gland | Carcinoma | 0/49 (0%) | 2/45 (4%) | 2/41 (5%)
Zymbal gland | Adenoma or carcinoma^c^ | 0/49 (0%) | 3/45 (7%) | 2/41 (5%)
Zymbal gland | Logistic regression tests^d^ | p = 0.135 | p = 0.108 | p = 0.219
Zymbal gland | Cochran-Armitage test^d^ | p = 0.157 | NA | NA
Zymbal gland | Fisher’s exact test^d^ | NA | p = 0.106 | p = 0.205
Female | | 0 | 1,240 (80) | 2,500 (165)
Zymbal gland | Hyperplasia | 1/36 (3%) | 0/37 (0%) | 0/35 (0%)
Zymbal gland | Adenoma | 0/36 (0%) | 0/37 (0%) | 2/35 (6%)
Zymbal gland | Carcinoma | 0/36 (0%) | 1/37 (3%) | 1/35 (3%)
Zymbal gland | Adenoma or carcinoma^e^ | 0/36 (0%) | 1/37 (3%) | 3/35 (9%)
Zymbal gland | Logistic regression tests^d^ | p = 0.055 | p = 0.492 | p = 0.116
Zymbal gland | Cochran-Armitage test^d^ | p = 0.028 | NA | NA
Zymbal gland | Fisher’s exact test^d^ | NA | p = 0.507 | p = 0.115
Thyroid gland | Hyperplasia | 1/50 (2%) | 0/48 (0%) | 1/50 (2%)
Thyroid gland | Follicular cell adenoma or carcinoma^f^ | 0/50 (0%) | 0/48 (0%) | 3/50 (6%)
Thyroid gland | Logistic regression trend test^d^ | p = 0.033 | NR | p = 0.110
Thyroid gland | Cochran-Armitage trend test^d^ | p = 0.016 | NA | NA
Thyroid gland | Fisher’s exact test^d^ | NA | NR | p = 0.121

a Bucher et al. (1990); NTP (1989).

b Daily doses in mg/kg-day were calculated by Bucher et al. (1990).

c Historical incidence at the study laboratory (mean ± SD): 4/599 (0.7 ± 1.0%); historical incidence in NTP studies: 19/1,936 (1.0 ± 1.7%, range 0−8%).

d The p-values in the control incidence are for the trend test for combined tumor incidence. The p-values in the exposure group incidence columns are for pairwise comparisons between that dose group and the controls for combined incidence of adenoma or carcinoma. The logistic regression test regards tumors in animals dying before terminal kill as nonfatal. The Cochran-Armitage and Fisher’s exact tests directly compare the overall incidence rates.

e Historical incidence at the study laboratory (mean ± SD): 1/649 (0.2 ± 0.6%); historical incidence in NTP studies: 11/1,983 (0.6 ± 1.3%, range 0−6%).

f Historical incidence at the study laboratory (mean ± SD): 5/627 (0.8 ± 1.3%); historical incidence in NTP studies: 19/1,938 (1.0 ± 1.2%, range 0−4%).

NA = not applicable; NR = not reported; NTP = National Toxicology Program; PETN = pentaerythritol tetranitrate; SD = standard deviation.