# APPENDIX A SCREENING PROVISIONAL VALUES

For the reasons noted in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional cancer toxicity values for pentaerythritol tetranitrate (PETN). However, information is available for this chemical, which although insufficient to support derivation of a provisional toxicity value under current guidelines, may be of limited use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with deriving an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

A National Toxicology Program (NTP) 2-year bioassay in rats and mice is available for developing a screening provisional oral slope factor (p-OSF) (Bucher et al., 1990; NTP, 1989). In the rat study, “Equivocal Evidence of Carcinogenicity” was observed in female and male rats based on marginal increases in combined incidence of rare Zymbal gland adenomas and carcinomas. There was also a marginal increase in the combined incidence of thyroid gland follicular cell adenomas and carcinomas in female rats. Although the NTP (1989) concluded that thyroid gland tumors were not related to PETN because there were no statistical indications of increased follicular cell adenomas or carcinomas, or increased follicular cell hyperplasia in males, the U.S. EPA considers suggestive evidence from a single sex to be informative. In the mouse study, there was no evidence of carcinogenicity.

Benchmark dose (BMD) modeling was performed for Zymbal gland tumors in female rats (see Table A-1; additional BMD details in Appendix C). Rationale for modeling marginal increases for Zymbal gland tumors include a significant dose-related trend in females (see Table B-5) and evidence for potential biological relevance based on their presence in every group of chronically treated rats and one high-dose female in the companion subchronic study (Bucher et al., 1990; NTP, 1989). Thyroid gland tumors in females were also BMD modeled because there was a significant dose-related trend in these tumors.

Before modeling, all doses were converted to human equivalent doses (HEDs) using 3/4 body-weight (BW^3/4^) scaling (U.S. EPA, 2005), according to the equation below:

HED = dose × ( BW_a_ ÷ BW_h_ )^1 / 4^

where

- Dose = average daily animal dose (ADD)
- BW_a_ = study-specific, time-weighted, body weight averages (TWA) for rat (see Table 3B footnote)
- BW_h_ = human body weight [70 kg; U.S. EPA (2011c)]

The animal doses, calculated HED values, and associated Zymbal gland tumor and thyroid tumor incidences are provided in Table A-1.

Table A-1 Animal Doses, HEDs, and Zymbal and Thyroid Gland Adenoma or Carcinoma Incidences in Female Rats Exposed Orally to PETN^a^

Animal Dose mg/kg-d | HED mg/kg-d | Zymbal Gland Adenoma or Carcinoma Incidence | Thyroid Gland Adenoma or Carcinoma Incidence
0 | 0 | 0/36 | 0/50
80 | 20 | 1/37 | 0/48
165 | 41.3 | 3/35 | 3/50

a Bucher et al. (1990); NTP (1989).

HED = human equivalent dose; PETN = pentaerythritol tetranitrate.

BMD modeling of the data on incidences of Zymbal and thyroid gland adenomas or carcinomas in female rats (Bucher et al., 1990; NTP, 1989) yielded the 10% benchmark dose lower confidence limit (BMDL_10_) (HED) values shown in Table A-2. Modeling procedures and results are described in detail in Appendix C.

Table A-2 BMD Model Results for Zymbal and Thyroid Gland Tumors in Female Rats^a^

Reference | Tumor Endpoint | Model Type | Goodness-of-Fit p-Value | BMD_10_ (HED) mg/kg-d | BMDL_10_ (HED) mg/kg-d | p-OSF (mg/kg-d)^−1^
Bucher et al. (1990); NTP (1989) | Zymbal gland adenoma or carcinoma in female rats | Multistage-Cancer-1st degree | 0.9224 | 56 | 27 | 3.7 × 10^−3^
Bucher et al. (1990); NTP (1989) | Thyroid gland adenoma or carcinoma in female rats | Multistage-Cancer-2nd degree | 0.7050 | 60 | 40 | 2.5 × 10^−3^
Bucher et al. (1990); NTP (1989) | Combined Zymbal adenoma or carcinoma, or thyroid adenoma or carcinoma | MS-Combo | NA | 36 | 23 | 4.3 × 10^−3^

a Bucher et al. (1990); NTP (1989).

BMD = benchmark dose; BMDL = benchmark dose lower confidence limit (subscripts denote BMR: i.e., 10 = exposure concentration associated with 10% extra risk); BMR = benchmark response; HED = human equivalent dose; NA = not applicable; p-OSF = provisional oral slope factor.

The BMDL_10_ (HED) of 23 mg/kg-day for the combined incidence of thyroid and Zymbal gland tumors was used as the point of departure (POD) for calculating the screening p-OSF as it was the lowest POD, compared with either of the individual tumor types. Because the study (Bucher et al., 1990; NTP, 1989) was conducted for the full lifetime of the rats (2 years), no adjustment for less-than-lifetime observation was necessary. The mode of action (MOA) by which PETN might induce Zymbal or thyroid gland tumors is not known; in the absence of definitive information, a linear approach was used to obtain the slope from the POD. The screening p-OSF of 4.3 × 10^−3^ (mg/kg-day)^−1^ was derived as follows:

Screening p-OSF = BMR ÷ BMDL_10_ ( HED ) = 0.1 ÷ 23 mg / kg-day = 4.3 × 10^− 3^ ( mg / kg-day )^− 1^