# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Jeffry L. Dean II, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Paul G. Reinhart, PhD, DABT
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## CONTRIBUTOR

- Channa Keshava, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC
- Ingrid L. Druwe, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Deborah Segal, MHS
  Center for Public Health and Environmental Assessment, Washington, DC
- Shana White, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Michelle M. Angrish, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC
- John Stanek, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## PRIMARY EXTERNAL REVIEWERS

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.