# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

Provisional reference dose (p-RfD) values are not derived because an RfD value is available on the U.S. EPA’s IRIS database (U.S. EPA, 1987).

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

Available inhalation studies include peer-reviewed subchronic neurotoxicity studies in rats (Li et al., 1999), peer-reviewed developmental studies in rats and rabbits (Klimisch and Hellwig, 1995), and an unpublished, two-generation study in rats (Nemec, 2003).

In peer-reviewed studies, the only treatment-related effect identified was slightly decreased response to stimuli during daily exposures at ≥782 mg/m^3^ (HEC_ER_ = 140 mg/m^3^) in the 13- and 14-week rat studies by Li et al. (1999). However, this transient CNS depression was considered an acute response by the study authors, and no additional information was identified to suggest that these effects are an indicator of an emerging subchronic neurological effect. Rapid, reversible CNS depression has been observed in animals following acute exposure to very high concentrations of isobutyl alcohol (see Table 4B). None of the available inhalation studies indicate more serious or permanent alterations in the nervous system following exposure to isobutyl alcohol. However, due to a lack relevant chronic exposure characterization, it is not possible to definitively conclude that these transient effects will not manifest at later life stages. In the Li et al. (1999) study, the absence of subchronic neurological effects is supported by the lack of exposure assessed outside of the daily exposure period (FOB, motor activity, SCOB) and no supporting morphological or histological evidence of damage to neurological tissues. However, a subjectively observed (non-quantitated) decrease in response to chamber brushing was observed for all exposed rats on days of exposure. Therefore, the highest concentration of 7,725 mg/m^3^ (HEC_ER_ = 1,379 mg/m^3^) in the subchronic studies by Li et al. (1999) is considered by the U.S. EPA to be a NOAEL for subchronic effects. No toxicologically relevant effects (including decreased fetal pup body weight) were noted in the developmental studies by Klimisch and Hellwig (1995) at concentrations up to 10,100 mg/m^3^ (HEC_ER_ = 2,525 mg/m^3^) in rats or 10,000 mg/m^3^ (HEC_ER_ = 2,500 mg/m^3^) in rabbits.

In the unpublished two-generation study by Nemec (2003), the U.S. EPA identified the lowest concentration as a LOAEL based on decreased F_1_ and F_2_ male and female pup postnatal body weight at concentrations ≥1,476 and 1,458 mg/m^3^ (HEC_ER_ = 369.0 and 364.5 mg/m^3^), respectively. Because the only toxicologically relevant effect following repeated inhalation exposure to isobutyl alcohol was identified in an unpublished study, the inhalation database is considered inadequate to support derivation of provisional reference values. However, the non-peer-reviewed, two-generation study provides sufficient data to develop screening subchronic and chronic provisional reference concentration (p-RfC) values based on developmental effects (see Appendix A).

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

A summary of the noncancer provisional reference values is shown in Table 6.

Table 6 Summary of Noncancer Reference Values for Isobutyl Alcohol (CASRN 78-83-1)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UF_C_ | Principal Study
Subchronic p-RfD (mg/kg-d) | NDr
Chronic p-RfD (mg/kg-d) | Oral RfD value of 0.3 mg/kg-d is available on IRIS (U.S. EPA, 1987)
Screening subchronic p-RfC (mg/m^3^) | Rat/both | Developmental (decreased F_2_ pup body weights) | 1 | LOAEL | 364.5 | 300 | Nemec (2003)
Screening chronic p-RfC (mg/m^3^) | Rat/both | Developmental (decreased F_2_ pup body weights) | 4 × 10^−1^ | LOAEL | 364.5 | 1,000 | Nemec (2003)

HEC = human equivalent concentration; HED = human equivalent dose; IRIS = Integrated Risk Information System; NOAEL = no-observed-adverse-effect level; NDr = not determined; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; RfD = oral reference dose; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE (WOE) DESCRIPTOR

Table 7 identifies the cancer WOE descriptor for isobutyl alcohol. No adequate cancer data are available. In general, available genotoxicity assays of isobutyl alcohol (see Table 4A) indicate that isobutyl alcohol is not a genotoxic agent. Under the U.S. EPA (2005) cancer guidelines, the available data are inadequate for an assessment of human carcinogenic potential, so the cancer WOE descriptor for isobutyl alcohol is “Inadequate Information to Assess the Carcinogenic Potential” (for both the oral and inhalation routes of exposure).

Table 7 Cancer WOE Descriptor for Isobutyl Alcohol

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | There are no human carcinogenicity data identified to support this descriptor.
“Likely to Be Carcinogenic to Humans” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | This descriptor is selected due to the lack of any adequate studies evaluating carcinogenicity of isobutyl alcohol.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available.

NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

Due to lack of adequate carcinogenicity data for isobutyl alcohol, derivation of cancer risk estimates is precluded (see Table 8).

Table 8 Summary of Cancer Risk Estimates for Isobutyl Alcohol (CASRN 78-83-1)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.