# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

Tables 3A and 3B provide overviews of the relevant inhalation noncancer and inhalation and oral cancer evidence bases, respectively, for isobutyl alcohol, and include all potentially relevant repeated-dose subchronic, and chronic studies, as well as reproductive and developmental toxicity studies, evaluated as medium or high confidence during systematic review (see Appendix C for more details). Oral noncancer data were not reviewed or included in this document because there is an existing Integrated Risk Information System (IRIS) oral reference dose (RfD). Principal studies used in the PPRTV assessment for derivation of provisional toxicity values are identified in bold. The phrase “statistical significance” and term “significant,” used throughout the document, indicate a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for Isobutyl Alcohol (CASRN 78-83-1)

Category^a^ | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry^b^ | Critical Effects | NOAEL^b^ | LOAEL^b^ | Reference (comments) | Notes^c^
Human
1. Oral (mg/kg-d)
NV
2. Inhalation (mg/m^3^)
NV
Animal
1. Oral (mg/kg-d)
NV
2. Inhalation (mg/m^3^)
Subchronic | 10–20 M/20 F, Sprague Dawley rat, whole-body vapor inhalation, 6 h/d, 4–5 d/wk, 3 mo (14 wk); Reported analytical concentrations: 0, 258, 1,044, 2,548 ppm | 0, 140, 565.2, 1,379 | No toxicologically relevant effects | 1,379 | NDr | Li et al. (1999); Li and Kaempfe (1996) | PR; NPR, GLP
Subchronic | 10 M, Sprague Dawley rat, whole-body vapor inhalation, 6 h/d, 5 d/wk, 3 mo (13 wk)); Reported analytical concentrations: 0, 258, 1,045, 2,547 ppm | 0, 140, 565.7, 1,379 | No toxicologically relevant effects | 1,379 | NDr | Li et al. (1999); Branch et al. (1996) | PR; NPR, GLP
Reproductive/Developmental | 30 M/30 F, Crl:CD (SD) IGS BR rat, whole-body vapor inhalation, 6 h/d, 7 d/wk, 70 d prior to mating through weaning (F_0_) with the exception of GD 20 to LD 5; exposure in utero to LD 28, direct exposure from weaning through mating to LD 21 (F1); exposure in utero to LD 21 (F2); Reported analytical concentrations: 0, 500, 1,008, 2,522 ppm (F_0_ adults/F_1_ pups); 0, 494, 1,012, 2,521 ppm (F_1_ adults/F_2_ pups) | 0, 369.0, 743.8, 1,861 (F_0_/F_1_ pups); 0, 364.5, 746.8, 1,861 (F_1_ adults/F_2_ pups) | Biologically significant decreases (≥5%) in F_1_ and F_2_ male and female pup body weights at multiple postnatal time points | NDr | 369.0 (F_1_ pups); 364.5 (F_2_ pups) | Nemec (2003) | NPR, PS, GLP
Developmental | 25 F SPF-Wistar rat, whole-body vapor inhalation, 6 h/d, GDs 6–15; Reported analytical concentrations: 0, 0.49, 2.50, 10.10 mg/L | 0, 123, 625.0, 2,525 | No toxicologically relevant effects | 2,525 | NDr | Klimisch and Hellwig (1995) | PR, GLP
Developmental | 15 F Himalayan rabbits, whole-body vapor inhalation, 6 h/d, GDs 7–19; Reported analytical concentrations: 0, 0.5, 2.51, 10.00 mg/L | 0, 125, 627.5, 2,500 | No toxicologically relevant effects | 2,500 | NDr | Klimisch and Hellwig (1995) | PR, GLP

a Duration categories are defined as follows: Acute = exposure for ≤24 hours; short term = repeated exposure for 24 hours to ≤30 days; long term (subchronic) = repeated exposure for >30 days ≤10% life span for humans (>30 days up to approximately 90 days in typically used laboratory animal species); and chronic = repeated exposure for >10% life span for humans (>~90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002b).

b Dosimetry: Doses are presented as HECs (in mg/m^3^) for inhalation noncancer effects. The HEC was calculated by treating isobutyl alcohol as a Category 3 gas and using the following equation from the U.S. EPA (1994) methodology: HECER = exposure level (mg/m^3^) × (hours/day exposed ÷ 24 hours) × (days/week exposed ÷ 7 days) × ratio of blood-gas partition coefficient (animal:human), using a default coefficient of 1 because the rat blood-air partition coefficient of 880 is greater than the range of 541–578 reported for human blood-air partition coefficients and a blood-air partition coefficient for isobutyl alcohol in rabbits has not been determined.

c Notes: NPR = not peer reviewed; PR = peer reviewed; PS = principal study; GLP = reported as adhering to Good Laboratory Practices standards.

ER = extrarespiratory; F = female(s); GD = gestation day; HEC = human equivalent concentration; LD = lactation day; LOAEL = lowest-observed-adverse-effect level; M = male(s); NDr = not determined; NOAEL = no-observed-adverse-effect level; NV = not evaluated.

Table 3B Summary of Potentially Relevant Cancer Data for Isobutyl Alcohol (CASRN 78-83-1)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference (comments) | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

## 2.1 HUMAN STUDIES

The three human studies identified in the literature search were considered low confidence or uninformative during study evaluation (see Figure C-2). The results from these studies are briefly summarized in Section 2.3.2 but they were not considered adequate for derivation of a provisional toxicity value.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures (Cancer Studies Only)

One animal oral cancer study was identified from the literature search (Dow Chemical, 1992); however, it was considered uninformative (see Figure C-2). The results from this study are briefly summarized in Section 2.3.3 but the study was not considered adequate for derivation of a provisional toxicity value.

### 2.2.2 Inhalation Exposures

Five inhalation publications, including two subchronic inhalation studies in rats (Li et al., 1999), one rat and one rabbit developmental study (Klimisch and Hellwig, 1995), and one two-generation study in rats (Nemec, 2003), were identified from the literature search and considered either medium or high confidence.

#### Subchronic Studies

##### Li et al. (1999); Li and Kaempfe (1996): Experiment 1

The subchronic general toxicity and neurotoxicity effects of isobutyl alcohol were evaluated in adult male and female rats in a peer-reviewed, published study by Li et al. (1999). Additional methodological details and data were available in an unpublished report by Li and Kaempfe (1996).

Commercially obtained Sprague Dawley rats (10–20/sex/group), 8 weeks of age at the start of exposure, were exposed whole body to isobutyl alcohol (99.9% purity) vapors at nominal concentrations of 0, 250, 1,000, or 2,500 ppm for 6 hours/day for 14 weeks (at least 70 exposures). Exposure occurred 4 days/week during Weeks 4, 8, and 13 (when neurobehavioral tests were conducted) and 5 days/week for remaining weeks. Measured analytical concentrations were 0, 258, 1,044, and 2,548 ppm (0, 782, 3,165, and 7,725 mg/m^3^, respectively, as calculated by the U.S. EPA using a molecular weight of 74.123 g/mol). Twenty rats/sex/group were included in the control and high-exposure groups; 10/sex/group were included in the low- and mid-exposure groups. Experimental groups included Group 1, a neuropathology group consisting of 5 randomly selected rats/sex/group; Group 2, a general toxicity group consisting of 5/sex/group; and Group 3, consisting of the remaining 10 animals in the control and high-exposure groups.

The animals were observed twice daily for mortality and clinical signs of toxicity, including subjective assessments of reaction to brushing and tapping of the exterior walls of the chamber during the last hour of exposure. During weekly body-weight measurements, more detailed observations for signs of toxicity were recorded, including palpation for masses. Food consumption was recorded weekly. Ophthalmoscopic examinations were performed prior to study initiation and during Week 14 of exposure in the control and high-exposure animals only. Behavioral tests (functional observational battery [FOB] and motor activity) were conducted prior to initiation of exposure and during Weeks 4, 8, and 13 on all but five animals/sex in the control and high-exposure groups. The animals were not exposed to isobutyl alcohol on the days of behavioral testing. At the end of exposure, Group 1 was sacrificed for the collection of a complete set of neurological tissues, including the brain (olfactory bulbs, forebrain, cerebrum, cerebellum, midbrain, pons, and medulla oblongata), spinal cord (cervical, thoracic, and lumbar segments), dorsal and ventral spinal nerve roots with dorsal root ganglia (C3–C6, L1–L4), Gasserian ganglion, sciatic, tibial, and sural nerves. However, only tissues from the control and high-exposure groups were examined microscopically. The one female sacrificed moribund from the high-exposure group was also examined for neuropathological lesions. Testes and epididymides of males from Group 1 were also removed, weighed, and fixed for histopathological examination.

In Group 2, blood was drawn at terminal necropsy for hematology (total erythrocyte count [red blood cells (RBCs)], total leukocyte count [white blood cells (WBCs)], hematocrit [Hct], hemoglobin [Hb], platelets, mean corpuscular volume [MCV], mean corpuscular hemoglobin [MCH], mean corpuscular hemoglobin concentration [MCHC], activated partial thromboplastin time [APTT], and leukocyte differential), and serum clinical chemistry (blood urea nitrogen [BUN], creatinine, glucose, total protein, albumin, globulin, glutamic pyruvic transaminase [SGPT]/alanine aminotransferase [ALT], alkaline phosphatase, gamma glutamyl transpeptidase, glutamic oxaloacetic transaminase [SGOT]/aspartate aminotransferase [AST], creatine phosphokinase, total and direct bilirubin, cholesterol, sodium, potassium, calcium, chloride, and phosphorus). Group 2 animals were grossly examined, and organs (brain, lungs, liver, kidneys, adrenals, testes, and epididymides) were weighed. Select tissues (adrenals, brain, epididymides, eyes, gross lesions, heart, kidneys, liver, lungs, nose sections, ovaries, skin, spleen, testes, uterus, and vagina) were fixed for histological analysis.

While Group 3 was intended as a recovery group for neurobehavior, these animals were sacrificed instead at the end of the exposure along with Groups 1 and 2 because no persistent neurobehavioral effects were observed during the study. Males from Group 3 underwent gross necropsy, and testes and epididymides were weighed and fixed for histopathological examination. Females from Group 3 underwent gross necropsy only. Statistical analysis of FOB, motor activity, and rearing data consisted of Levene’s test for homogeneity, Dunnett’s multiple comparison test, and analyses of variance (ANOVAs) using baseline values as covariates (analyses of covariance [ANCOVAs]) for parameters with repeated measures. For other endpoints, Bartlett’s test was used for homogeneity of variances, followed by either Dunnett’s test and linear regression, or nonparametric Kruskal-Wallis, Jonckheere’s, and/or Mann-Whitney U test for trend. Incidence data were analyzed using Fisher’s exact test (one-tailed). The Grubb’s test was used to detect outliers in organ-weight data.

Quantitative data extraction for Experiment 1 (https://hawcprd.epa.gov/ani/experiment/100500184/) can be found in the Health Assessment Workspace Collaborative (HAWC) database; links to specific data sets are included below for ease of review. One moribund female from the high-exposure group was sacrificed at approximately 2 months due to development of lymphoblastic leukemia of the vertebral column and surrounding tissues; all other males and females survived. A decrease in response to chamber brushing was subjectively observed in all examined males (https://hawcprd.epa.gov/ani/endpoint/100503868/) and females (https://hawcprd.epa.gov/ani/endpoint/100503870/) exposed to isobutyl alcohol when tested during the last hour of daily exposure (every exposure day throughout the study); control animals responded normally to chamber brushing. Some rats from the high-exposure group also showed a decrease in response to chamber tapping during the last hour of daily exposure (first 3 days of exposure only), with three males (https://hawcprd.epa.gov/ani/endpoint/100503869/) and four females (https://hawcprd.epa.gov/ani/endpoint/100503871/) affected during Day 1 of exposure and 0–2 rats/sex affected during Exposure Days 2 and 3. All high-exposure animals responded normally to cage tapping after the first 3 exposure days, and all control animals and animals in the lower exposure groups responded normally throughout the study. No abnormal clinical signs were observed immediately after cessation of daily exposures or during weekly detailed clinical assessments. No ophthalmological changes were reported in the control or high-exposure animals. Body weight and body-weight gain were comparable across study groups. Statistically significant increases in food consumption in males in the mid-exposure group were sporadic, and no exposure-response relationship was observed. No changes in food consumption were observed in females.

There were no statistically significant differences between treated and control groups in the FOB or motor activity testing at any time point throughout the study. No biologically relevant changes in hematology or clinical chemistry were observed. The few sporadic findings that reached statistical significance, including a 9–10% increase in RBC (https://hawcprd.epa.gov/ani/endpoint/100503545/), Hct (https://hawcprd.epa.gov/ani/endpoint/100503565/), and Hb (https://hawcprd.epa.gov/ani/endpoint/100503564/) in high-dose females and a <5% increase in serum calcium (https://hawcprd.epa.gov/ani/endpoint/100503529/) in mid-dose males, were not considered biologically relevant given the direction of change (increased) and a lack of exposure-response, respectively. A statistically significant trend for increased absolute kidney weight (https://hawc.epa.gov/ani/endpoint/100503513/) was observed in exposed males (increases of 4, 17, and 16% in low-, mid-, and high-exposure males, respectively); however, pairwise statistics did not identify any statistically significant effects between individual exposure groups and controls. No statistically significant trend or pairwise effects were observed in relative kidney weights in males (kidney:body weight (https://hawcprd.epa.gov/ani/endpoint/100503532/) [6, 9, 8%] or kidney:brain (https://hawcprd.epa.gov/ani/endpoint/100503535/) [4, 15, 15%]). Statistically significant positive trends were observed in absolute liver weight (https://hawc.epa.gov/ani/endpoint/100503514/) (−5, 9, 17%), liver:body weight (https://hawcprd.epa.gov/ani/endpoint/100503533/) (−3, 1, 9%), and liver:brain weight (https://hawc.epa.gov/ani/endpoint/100503536/) (−4, 9, 18%) in low-, mid-, and high-exposure males, respectively, but again, pairwise comparisons did not identify any statistically significant changes between groups. While select kidney and liver weights in males were elevated by >10%, these findings were not considered indicative of a biologically relevant effect because (1) there were no exposure-related changes in liver or kidney serum biochemistry indicative of a functional impairment, (2) there were no associated histochemical lesions in the liver or kidney, and (3) organ-weight changes were not observed in females. No exposure-related gross or microscopic lesions were identified in any of the evaluated organs. All observed gross and microscopic lesions, including those in perfusion-fixed neuronal tissues, were sporadic, occurred in small numbers, and/or did not exhibit concentration dependence.

The highest exposure concentration (7,725 mg/m^3^) is a no-observed-adverse-effect level (NOAEL) associated with repeated exposure. No biologically relevant effects were noted in body weight, hematology, clinical chemistry, or histopathology. Biologically significant increases in liver and kidney weights in male animals were noted but not identified as lowest-observed-adverse-effect levels (LOAELs) because corroborating evidence was lacking. The transient central nervous system (CNS) depression observed only during daily exposure periods was considered an acute response to isobutyl alcohol by the study authors, and not an indicator of an emerging subchronic neurological effect. The absence of persistent subchronic neurological effects is supported by the lack of exposure-related findings in the FOB and motor activity analyses and no evidence of damage to neurological tissues. Analytical concentrations of 0, 782, 3,165, and 7,725 mg/m^3^ correspond to extrarespiratory effects human equivalent concentration (HEC_ER_) values of 0, 140, 565.2, and 1,379 mg/m^3^.^1^

##### Li et al. (1999); Branch et al. (1996): Experiment 2

Li et al. (1999) studied the subchronic neurotoxic effects of isobutyl alcohol in adult male Sprague Dawley (CD) rats using schedule-controlled operant behavior (SCOB) training. Additional methodological details and data are available in an unpublished report by Branch et al. (1996).

Commercially sourced Sprague Dawley rats were obtained at 5 weeks of age. After a 1-week acclimation period, 40 male rats were placed on a restricted diet (11–14 g/day, 7 days/week); water was available ad libitum. Male rats were trained to perform on the SCOB test in automated operant chambers. Briefly, SCOB training included 47-minute sessions in which the animals were trained to press a lever for food reinforcement using both fixed ratio (FR; rewarded only after a certain number of lever presses), and fixed interval (FI; rewarded for lever press only after a specified amount of time has elapsed). Rats were fully trained prior to exposure to isobutyl alcohol, starting with small ratios/intervals and progressing to a final schedule of four consecutive FR periods of 20 lever presses followed by two consecutive FI periods of 120 seconds. Most rats reached training criteria within 30 days; however, an additional 6 weeks of training was required for performance to be stable. The baseline performance for each animal was established 1 week prior to exposure (during Week 10 of training).

At 16 weeks of age, groups of trained male rats (10/group) were exposed to isobutyl alcohol (99.9% purity) vapors at nominal concentrations of 0, 250, 1,000, or 2,500 ppm for 6 hours/day, 5 days/week for 13 weeks (65 exposures), with sacrifice 1 week after the final exposure. Reported analytical concentrations were 0, 258, 1,045, and 2,547 ppm (782, 3,168, and 7,722 mg/m^3^, respectively, as calculated by the U.S. EPA using a molecular weight of 74.123 g/mol). Starting 1 week before the first exposure and continuing throughout the study, the animals were tested 5 days/week (before the daily exposure session) for SCOB performance (e.g., whether rats pushed the lever the appropriate number of times during the FR period and waited the appropriate amount of time between lever presses during FI periods). Overall motor activity and habituation were also recorded during SCOB testing. The animals were observed twice daily for mortality and clinical signs of toxicity, including subjective assessments of reactions to brushing and tapping of the exterior walls of the chamber during the last hour of exposure. Ophthalmoscopic examinations were conducted on all rats prior to study initiation and 3 days after the last exposure. Body weights were recorded weekly and prior to SCOB testing. During weekly body-weight measurements, more detailed observations for signs of toxicity were recorded, including palpation for masses. Gross necropsy was performed only in the event of a finding during detailed clinical observations. Only the SCOB data collected during the pretest week and during Weeks 4, 8, and 13 of exposure were statistically analyzed, including measures of SCOB performance, total motor activity, and motor activity habituation. Repeated measures analysis of covariance (REPANCOVA) using baseline values as covariates was used to analyze weekly mean values across time and exposure concentration. Levine’s test (p ≤ 0.01) was used to analyze homogeneity of variance, and Dunnett’s multiple comparison test was used to compare groups. Positive control data for SCOB tests were collected from 40 male rats prior to the study using d-amphetamine sulfate and chlorpromazine hydrochloride. The same dependent variables were measured in the experimental and positive control studies.

Quantitative data extraction for Experiment 2 (https://hawc.epa.gov/ani/experiment/100500185/) can be found in the HAWC database; links to specific data sets are included below for ease of review. No mortalities were observed. A decrease in response to chamber brushing (https://hawcprd.epa.gov/ani/endpoint/100503584/) was subjectively observed in all examined rats exposed to isobutyl alcohol when tested during the last hour of daily exposure (every exposure day throughout the study); control animals responded normally to chamber brushing. Control and exposed animals both responded normally to chamber tapping (https://hawc.epa.gov/ani/endpoint/100503585/) during the last hour of daily exposure throughout the study. No other exposure-related clinical signs were observed immediately before, during, or after daily exposure. No palpable masses were identified during detailed clinical observations, and no ophthalmological abnormalities were found. There were no consistent, exposure-related changes in body weight or body-weight gain in exposed animals, compared with controls. Results from SCOB testing indicated no statistically significant differences in SCOB performance between controls and treatment groups during any of the testing weeks. Positive control animals performed as expected in SCOB testing. The only notable observation at necropsy was swollen testes in one mid-exposure male; this finding was considered incidental.

The U.S. EPA has identified the highest exposure concentration (7,722 mg/m^3^) as a NOAEL based on a lack of toxicologically relevant effects associated with repeated exposure. As discussed for Experiment 1, the slight, transient CNS depression observed during daily exposure was considered by the study authors to be an acute response to isobutyl alcohol, and not an anticipated indicator of an emerging subchronic neurological effect; however, it is unclear if these transient effects would manifest under longer-duration exposures due to lack of experimental data. The absence of subchronic neurological effects is supported by the lack of exposure-related findings in the SCOB testing. The analytical concentrations of 782, 3,168, and 7,722 mg/m^3^ correspond to HEC_ER_ values of 0, 140, 565.7, and 1,379 mg/m^3^.^2^

#### Chronic Studies

No chronic inhalation studies of isobutyl alcohol have been identified.

#### Reproductive/Development Studies

##### Nemec (2003)

In an unpublished two-generation study, groups of Crl:CD (SD) IGS BR rats (30/sex/group) were exposed to clean filtered air or to isobutyl alcohol vapor concentrations of 500, 1,000, or 2,500 ppm (nominal) for 6 hours/day, 7 days/week via whole-body exposure (Nemec, 2003). Reported analytical mean concentrations were 500, 1,008, and 2,522 ppm (1,476, 2,975, and 7,444 mg/m^3^, respectively, as determined by the study authors) for the parental (F_0_) generation and F_1_ pups, and 494, 1,012, and 2,521 ppm (1,458, 2,987, and 7,442 mg/m^3^, respectively, as determined by the study authors) for F_1_ adults and F_2_ pups. Exposure for F_0_ rats began ∼70 days prior to mating, and continued in both sexes throughout mating, gestation, and lactation periods until postnatal day (PND) 28. During this time, exposure was stopped in F_0_ females between gestation day (GD) 20 and lactation day (LD) 5 to allow for parturition. On PND 4, F_1_ litters were culled to eight rats (preferably to four per sex). Prior to weaning, 30 F_1_ pups/sex/group were randomly selected to generate the F_2_ generation. Additional weanlings were kept as potential replacement animals. Mated F_0_ males and females were necropsied after F_1_ weaning. The remaining F_0_ animals were sacrificed on Study Day 133. The F_1_ offspring not selected for mating were sacrificed at weaning (PND 28). F_1_ animals selected for mating began direct exposure at weaning and were exposed in the same manner as F_0_animals from at least 70 days prior to mating until sacrifice. Second-generation (F_2_) offspring were exposed in utero, and during lactation until sacrifice. Mated F_1_ adults and F_2_ pups were sacrificed on PND 21.

All animals were observed twice daily and within 1 hour of exposure for mortality and clinical signs of toxicity. Subjective assessments of state of arousal and response to a loud-noise stimulus were included in the evaluations and were difficult to interpret due to reporting outcomes as results combined from different stimuli. Female estrous cycles were monitored beginning 21 days prior to pairing until evidence of mating was observed. F_0_ and F_1_ male and female body weights were recorded on Study Days 0, 1, 4, and 7, and weekly (males) thereafter. After mating, female body weights and food consumption were recorded on GDs 0, 4, 7, 11, 14, and 20 and LDs 1, 4, 7, 14, 21, and 28 (F_0_ females only). Gross necropsies were performed on all adult animals. Organ (adrenals, brain, epididymides, kidneys, liver, ovaries, pituitary, prostate, seminal vesicles with coagulating glands, spleen, testes, thymus gland, and uterus with oviducts and cervix) weights were recorded. Microscopic examinations were done on all gross lesions and select tissues (adrenal glands, cortex and medulla, brain, cervix, epididymis, caput, corpus and cauda, kidneys, liver, ovaries, pituitary, prostate, seminal vesicles, spleen, testis, thymus, uterus, and vagina) from 10 adults/sex/group from the control and high-exposure groups. Reproductive performance parameters included mating and fertility indices for F_0_ and F_1_ generations. Spermatogenic endpoints, including mean testicular and epididymal sperm counts, sperm production rate, motility, progressive motility, and percentage of morphologically normal sperm, were evaluated in F_0_ and F_1_ males. Litter endpoints examined included litter size, postnatal survival, and pup body weights on PNDs 1, 4, 7, and 21 for F_1_ and F_2_ pups and PNDs 28, 32, and 35 for F_1_ pups. Complete necropsies were performed on F_1_ and F_2_ pups that were sacrificed on PNDs 28 and 21, respectively. Select organ weights (brain, spleen, thymus gland) were recorded in pups at each sacrifice. Gross lesions were retained for histopathologic examination.

Mating and fertility data were analyzed using the χ^2^ test with Yates’ correction factor. For other endpoints, one-way ANOVA was used to determine intergroup differences followed by the Dunnett’s test if significant. The litter was used as the experimental unit where appropriate. Nonparametric data were subjected to the Kruskal-Wallis nonparametric ANOVA test followed by the Mann-Whitney U test, if significant. Using litter size as a covariant, parametric one-way ANCOVA was used to determine intergroup differences in mean offspring weights, followed by the Student’s t-test, if significant. The two-tailed Fisher’s exact test was used on histological findings to compare test groups to the control.

Quantitative data extraction for the two-generation study (https://hawcprd.epa.gov/ani/experiment/100500155/) can be found in the HAWC database; links to specific data sets are included below for ease of review. One F_0_ female in the low-exposure group was sacrificed in extremis after 91 days of exposure. No other F_0_ generation mortalities were observed, and there were no significant clinical signs of toxicity in any exposure group. Responses to stimuli (ear flick) were comparable between exposed and control animals. Overall, there were no exposure-related changes in body weights or body-weight gains for F_0_ males or females, and terminal body weights were comparable across all groups. Sporadic, but statistically significant, body-weight changes that did not exhibit a dose-response relationship included a 55% reduction in body-weight gain (https://hawc.epa.gov/ani/endpoint/100503864/) in middle exposure concentration F_0_ males during Study Days 84–91, a 7% increase in body weight (https://hawc.epa.gov/ani/endpoint/100503634/) in low-exposure F_0_ females on LD 28, and an 18-fold increase in body-weight gain (https://hawc.epa.gov/ani/endpoint/100503613/) in low-exposure F_0_ females during LDs 1–28. These changes in low-exposure females coincided with an increase in food efficiency in this group during lactation. Mean body weights and body-weight gains were comparable between all other exposure groups and controls throughout the study. Statistically significant reductions in food consumption were observed sporadically during the study in the high-exposure group, particularly in males, but the reductions were small (generally <5% decrease from controls) and did not coincide with statistically significant changes in body weight. There were no dose-response associations observed in F_0_ adult organ weights; however, sporadic statistically significant changes were observed. These sporadic changes in males included a 20% increase in absolute prostate (https://hawcprd.epa.gov/ani/endpoint/100503602/) weight in the mid-exposure group and 14–23% increases in relative prostate (https://hawc.epa.gov/ani/endpoint/100503595/) weight in the low- and mid-exposure groups, compared with controls. The study authors reported that because similar effects were not observed in high-exposure group animals, these changes were not attributable to the test article. In low-exposure females, the sporadic changes were limited to a 16% decrease in absolute pituitary (https://hawc.epa.gov/ani/endpoint/100509742/) weight. No statistically significant organ-weight changes were observed in the high-exposure groups for either sex. The single female euthanized in extremis had renal and liver necrosis; no exposure-related microscopic changes were observed in remaining F_0_ animals that survived until scheduled sacrifice.

The mating and fertility indices in F_0_ animals were not affected by exposure to isobutyl alcohol. The fertility index (https://hawcprd.epa.gov/ani/endpoint/100503614/) of 97% in low-exposure F_0_ females was statistically significantly higher than the fertility index of 73% in controls, but this was not considered biologically relevant. There were no differences in estrous cyclicity, time to coitus, or gestation length between exposed animals and controls. Overall, there were no statistically significant effects of exposure on any sperm parameters, including motility, sperm count, sperm production rates, or morphology in F_0_ males. Examination of sperm identified one F_0_ male in the high-exposure group with a low percentage of morphologically normal sperm (0.5% vs. a mean of 97.9% in controls). The study authors concluded that the percentages of morphologically normal sperm from other males in this exposure group were within the normal biological range for this species and strain.

No exposure-related effects were observed in F_1_ litter endpoints. Litter size, sex ratios, and mean number of pups were comparable across exposure groups. F_1_ pups in the low-exposure group showed a 10% decrease in survival between PND 4 and 28 (https://hawc.epa.gov/ani/endpoint/100503668/), but survival in this group was comparable to controls on PNDs 0–4 (https://hawcprd.epa.gov/ani/endpoint/100503667/). In the higher-exposure groups, survival was comparable to control on PNDs 0–4 (https://hawcprd.epa.gov/ani/endpoint/100503667/) and PNDs 4–28 (https://hawcprd.epa.gov/ani/endpoint/100503668/). Reductions in F_1_ pup body weights and body-weight gains were observed at various times during the postnatal period in all exposure groups. For the purposes of this PPRTV assessment, a ≥5% decrease in pup body weight is considered biologically significant by the U.S. EPA. In the low-exposure group, statistically and/or biologically (i.e., ≥5%) significant decreases in pup weight (7–18%) were observed in F_1_ males (https://hawcprd.epa.gov/ani/animal-group/100500377/) on PNDs 4–35 and F_1_ females (https://hawcprd.epa.gov/ani/animal-group/100500378/) on PNDs 1–35. In the mid-exposure group, statistically and/or biologically significant decreases in pup weight (7–13%) were observed in F_1_ males (https://hawcprd.epa.gov/ani/animal-group/100500377/) and F_1_ females (https://hawcprd.epa.gov/ani/animal-group/100500378/) on PNDs 7–35. Biologically relevant reductions in pup weight (5–8%) were also observed in the high-exposure group in F_1_ males (https://hawcprd.epa.gov/ani/animal-group/100500377/) and F_1_ females (https://hawc.epa.gov/ani/animal-group/100500378/) on PNDs 7–28. For body-weight gain, statistically significant decreases were observed in low-exposure F_1_ males (14–34%) on PNDs 4–7 (https://hawc.epa.gov/ani/endpoint/100503429/), 14–21 (https://hawcprd.epa.gov/ani/endpoint/100503431/), and PNDs 1–28 (https://hawc.epa.gov/ani/endpoint/100503432/) and females (10–40%) on PNDs 4–7 (https://hawc.epa.gov/ani/endpoint/100503445/), 14–21 (https://hawcprd.epa.gov/ani/endpoint/100503447/), 21–28 (https://hawcprd.epa.gov/ani/endpoint/100503448/), and 28–35 (https://hawc.epa.gov/ani/endpoint/100503451/). In the mid-exposure group, statistically significant decreases in body-weight gains (11–26%) were observed in F_1_ males on PNDs 4–7 (https://hawc.epa.gov/ani/endpoint/100503429/), 14–21 (https://hawc.epa.gov/ani/endpoint/100503431/), 28–32 (https://hawcprd.epa.gov/ani/endpoint/100503433/), and 28–35 (https://hawc.epa.gov/ani/endpoint/100503451/) and females on PNDs 4–7 (https://hawc.epa.gov/ani/endpoint/100503445/), 14–21 (https://hawc.epa.gov/ani/endpoint/100503447/), 28–35 (https://hawcprd.epa.gov/ani/endpoint/100503451/), and 32–35 (https://hawc.epa.gov/ani/endpoint/100503450/). In the high-exposure group, body-weight gains were significantly decreased by 12% in F_1_ males on PNDs 14–21 (https://hawc.epa.gov/ani/endpoint/100503431/). There were no notable necropsy findings or exposure-related organ-weight changes in F_1_ pups on PND 28. Sporadic organ-weight changes included a statistically significant 19% reduction in absolute thymus weight (https://hawc.epa.gov/ani/endpoint/100503640/) in low-exposure males and a 6% decrease in absolute brain weight (https://hawc.epa.gov/ani/endpoint/100503645/) in low-exposure females, with no significant effects at higher exposure levels. The mean days to balanopreputial separation in males and vaginal patency in females were not affected by exposure. Vaginal patency (https://hawcprd.epa.gov/ani/endpoint/100503649/) was slightly, but statistically significantly, delayed by 6% relative to controls in low-exposure females only; this was likely secondary to the observed decreases in body weight in this exposure group.

There were no significant exposure-related clinical findings, including response to stimuli, in either F_1_ males or females. Like the F_0_ animals, sporadic and transient changes in body weights and food consumption occurred in F_1_ adults, but without indication of concentration dependence. Reductions in body weights and/or body-weight gains that were evident in low- and mid-exposure groups during lactation persisted into adulthood, with small reductions (≤10%) occurring primarily in low- and mid-exposure males and only sporadically in females. At terminal sacrifice, statistically significant 7–8% decreases in F_1_ adult male body weight (https://hawcprd.epa.gov/ani/endpoint/100503678/) were observed in low- and mid-exposure groups, and a statistically significant 8% decrease in cumulative body-weight gain (https://hawcprd.epa.gov/ani/endpoint/100503679/) was observed in the low-exposure group only. No statistically significant changes were observed for F_1_ adult female terminal body weight (https://hawcprd.epa.gov/ani/endpoint/100503706/) or cumulative body-weight gain (https://hawcprd.epa.gov/ani/endpoint/100503711/). Slight (≤10%), but statistically significant, reductions in relative food consumption occurred in high-exposure F_1_ females during GDs 0–4 (https://hawcprd.epa.gov/ani/endpoint/100503865/), 11–14 (https://hawcprd.epa.gov/ani/endpoint/100503866/), and 0–20 (https://hawcprd.epa.gov/ani/endpoint/100503867/). Sporadic statistically significant changes in organ weights in F_1_ adults were not considered related to treatment due to lack of a clear exposure-related response (increased relative brain weight (https://hawc.epa.gov/ani/endpoint/100503692/) and relative thymus weight (https://hawc.epa.gov/ani/endpoint/100503697/) and decreased absolute liver weight (https://hawcprd.epa.gov/ani/endpoint/100503688/) in low-exposure males; reduced absolute pituitary weights (https://hawcprd.epa.gov/ani/endpoint/100503717/) in low- and mid-exposure females). At sacrifice, there were no gross or microscopic findings attributed to exposure. The mating and fertility indices in exposed adult F_1_ animals were comparable with controls. No exposure-related changes were observed in any other reproductive performance measures or in male sperm parameters.

Clinical observations and survival of F_2_ pups were comparable between exposed and control animals. Reductions in F_2_ pup body weight and body-weight gains were observed at various times during the postnatal period in all exposure groups. In the low- and mid-exposure groups, statistically and/or biologically (i.e., ≥5%) significant decreases in body weight (7–17%) were observed in F_2_ males (https://hawcprd.epa.gov/ani/animal-group/100500380/) and F_2_ females (https://hawcprd.epa.gov/ani/animal-group/100500379/) on PNDs 1–21. In the high-exposure group, statistically and/or biologically significant decreases in body weight (5–14%) were observed in F_2_ males (https://hawcprd.epa.gov/ani/animal-group/100500380/) and F_2_ females (https://hawcprd.epa.gov/ani/animal-group/100500379/) on PNDs 14 and 21 only. For body-weight gain, statistically significant decreases were observed in low-exposure F_2_ males (23–31%) on PNDs 1–4 (https://hawcprd.epa.gov/ani/endpoint/100503745/), 4–7 (https://hawcprd.epa.gov/ani/endpoint/100503746/), and 14–21 (https://hawc.epa.gov/ani/endpoint/100503748/) and females (21–25%) on PNDs 1–4 (https://hawcprd.epa.gov/ani/endpoint/100503762/), 4–7 (https://hawc.epa.gov/ani/endpoint/100503761/), and 14–21 (https://hawcprd.epa.gov/ani/endpoint/100503764/). In the mid-exposure group, statistically significant decreases in body-weight gain of 25–27% were observed on PNDs 14–21 in males (https://hawcprd.epa.gov/ani/endpoint/100503748/) and females (https://hawc.epa.gov/ani/endpoint/100503764/). In the high-exposure group, a statistically significant 21% decrease in body-weight gain was observed in F_2_ female pups on PNDs 14–21 (https://hawcprd.epa.gov/ani/endpoint/100503764/).

No notable necropsy findings in F_2_ pups were reported. Sporadic, but statistically significant, changes in organ weights in F_2_ pups on PND 21 were not considered related to treatment due to lack of a clear exposure-response relationship. Sporadic changes in F_2_ male pups included a 15–16% increase in relative brain weight (https://hawcprd.epa.gov/ani/endpoint/100503752/), but not absolute brain weight (https://hawcprd.epa.gov/ani/endpoint/100503749/), in the low- and mid-exposure groups and a 24% decrease in absolute spleen weight (https://hawcprd.epa.gov/ani/endpoint/100503750/), but not relative spleen weight (https://hawc.epa.gov/ani/endpoint/100503753/), in the mid-exposure group only. Similarly, sporadic changes in F_2_ female pups included a 13% increase in relative brain weight (https://hawcprd.epa.gov/ani/endpoint/100503768/), but not absolute brain weight (https://hawcprd.epa.gov/ani/endpoint/100503765/) in the low-, mid-, and high-exposure groups; a 19–28% decrease in absolute spleen weight (https://hawcprd.epa.gov/ani/endpoint/100503766/) across all exposure groups; and a 24% decrease in relative spleen weight (https://hawcprd.epa.gov/ani/endpoint/100503769/) in the mid-exposure group only. At gross necropsy, there were no exposure-related findings in F_2_ pups. Dilated renal pelvis was observed in two pups each in the low- and mid-exposure groups, but the incidences were not significant if analyzed at either the individual (https://hawc.epa.gov/ani/endpoint/100503736/) or litter (https://hawcprd.epa.gov/ani/endpoint/100503737/) level.

The U.S. EPA considers the lowest concentration (1,476 mg/m^3^ in F_1_ pups and 1,458 mg/m^3^ in F_2_ pups) a developmental LOAEL based on decreased F_1_ and F_2_ male and female pup body weights at multiple postnatal time points. There were biologically significant (≥5%) decreases in body weights of pups of both sexes at all concentrations in both generations. The highest concentration (7,444 mg/m^3^ in F_0_ adults/F_1_ pups and 7,442 mg/m^3^ in F_1_ adults/F_2_ pups) is a systemic and reproductive NOAEL based on a lack of toxicologically relevant effects on systemic and reproductive endpoints. Analytical concentrations of 0, 1,476, 2,975, and 7,444 mg/m^3^ for F_0_ adults and F_1_ pups correspond to HEC values of 0, 369.0, 743.8, and 1,861 mg/m^3^, for extrarespiratory effects. Analytical concentrations of 0, 1,458, 2,987, and 7,442 mg/m^3^ for F_1_ adults and F_2_ pups correspond to HEC values of 0, 364.5, 746.8, and 1,861 mg/m^3^, respectively, for extrarespiratory effects.^3^

##### Klimisch and Hellwig (1995): Rats

A published, peer-reviewed developmental toxicity study by Klimisch and Hellwig (1995) was conducted in female SPF-Wistar rats. Mated females (25/group) were exposed whole body to nominal concentrations of isobutyl alcohol (99.8% purity) vapors at 0, 0.5, 2.5, or 10 mg/L (0, 500, 2,500, or 10,000 mg/m^3^, respectively, as converted by the U.S. EPA) for 6 hours/day on GD 6–15. Control groups were exposed to clean air. Measured analytical mean concentrations were 0, 0.49, 2.50, or 10.10 mg/L (0, 490, 2,500, or 10,100 mg/m^3^, respectively, as converted by the U.S. EPA). The animals were weighed at 3-day intervals and observed daily for clinical signs of toxicity. At sacrifice on GD 20, all dams underwent gross necropsy, and the uteri were weighed. The numbers of corpora lutea, implants, live fetuses, and early and late resorptions were recorded. Fetuses were sexed, weighed, and examined externally. Visceral examinations were conducted on approximately half of the fetuses, and skeletal examinations on the remaining fetuses from each litter. Statistical analysis of data included the Dunnett’s test for maternal body weights, fetal body weights, and survival data. The Fisher’s exact test was used to evaluate maternal mortality, conception, and fetal examinations.

Quantitative data extraction for this rat developmental toxicity study (https://hawc.epa.gov/ani/experiment/100500165/) can be found in the HAWC database; links to specific data sets are included below for ease of review. No mortalities were observed, and no clinical signs of toxicity related to exposure were reported. No exposure-related changes were observed in maternal body-weight gains during exposure or through GD 20 (with or without correction for gravid uterine weight); absolute body weights were not reported. Uterine weights were comparable across all groups. Litter parameters, including corpora lutea, dead implants, live fetuses, implantation, and placental weight, were comparable across all groups. A statistically significant decrease in postimplantation loss (https://hawc.epa.gov/ani/endpoint/100503088/) was observed in the high-exposure group (4.2%) compared with controls (10%); however, this effect is not considered toxicologically relevant. No statistically significant changes in preimplantation loss were observed. Fetal body weights were comparable between exposure and control groups. There were no exposure-dependent increases in visceral or skeletal abnormalities. The only statistically significant change was a decreased fetal incidence in dilated renal pelvis (https://hawc.epa.gov/ani/endpoint/100503337/) in the low-exposure group (31%), compared with controls (47%); however, this effect is not considered toxicologically relevant, and no changes were observed at higher exposure levels.

The U.S. EPA considers the highest concentration (10,100 mg/m^3^) a maternal and developmental NOAEL, based on the lack of toxicologically relevant effects. The reported concentrations of 0, 490, 2,500, and 10,100 mg/m^3^ correspond to HEC values of 0, 123, 625.0, and 2,525 mg/m^3^ for extrarespiratory effects.^4^

##### Klimisch and Hellwig (1995): Rabbits

A published, peer-reviewed developmental toxicity study by Klimisch and Hellwig (1995) was conducted in female Himalayan rabbits. Inseminated females (15/group) were exposed whole body to isobutyl alcohol (purity 99.8%) vapors at 0, 0.5, 2.5, or 10 mg/L (0, 500, 2,500, or 10,000 mg/m^3^, respectively, as converted by the U.S. EPA) for 6 hours/day on GD 7–19. Reported analytical mean concentrations were 0, 0.5, 2.51, or 10.00 mg/L (0, 500, 2,510, and 10,000 mg/m^3^, respectively, as converted by the U.S. EPA). Animals in control groups were exposed to clean air. The animals were observed daily for clinical signs of toxicity, and body weights were recorded at 3-day intervals. All dams underwent gross necropsy on GD 29 and the uteri were weighed. The numbers of corpora lutea, implants, live fetuses, and early and late resorptions were recorded. Fetuses were sexed, weighed, and examined externally. Soft tissue and skeletal examinations were conducted on all fetuses. Statistical analysis of data included the Dunnett’s test for maternal body weights, fetal body weights, and survival data. The Fisher’s exact test was used to evaluate maternal mortality, conception, and fetal examinations.

Quantitative data extraction for the rabbit developmental toxicity study (https://hawcprd.epa.gov/ani/experiment/100500166/) can be found in the HAWC database; links to specific data sets are included below for ease of review. One doe in the mid-exposure group died on Day 24, and a single doe in the high-exposure group was sacrificed on Day 21 due to spontaneous abortion. The deaths were not considered exposure-related. No clinical signs of toxicity were reported. There were no statistically significant changes in maternal body weight, body-weight gain, or uterine weight between the exposed and control does. Litter parameters were comparable across all groups, including corpora lutea, implantations, dead implants, pre- and postimplantation loss, and live fetuses. There was a slight, but statistically significant, 12% increase in mean placental (https://hawcprd.epa.gov/ani/endpoint/100503324/) weight in the mid-exposure group, compared with control, but statistically significant changes were not observed in the low- or high-exposure groups. There were no statistically or biologically significant changes in fetal body weights. No exposure-dependent increases in visceral or skeletal abnormalities were observed. A statistically significant increase in the overall fetal incidence (https://hawcprd.epa.gov/ani/endpoint/100503408/) of a specific heart variation (traces of interventricular foramen/septum membranaceum) occurred in the high-exposure group (12/92 = 13%), compared with concurrent controls (2/105 = 2%); however, the litter incidence (https://hawcprd.epa.gov/ani/endpoint/100503409/) for this variation in the high-exposure group (5/13 = 38%) was not statistically different from concurrent controls (2/15 = 13%).

The highest concentration (10,000 mg/m^3^) is a maternal and developmental NOAEL based on the lack of toxicologically relevant effects. Although there was a significant increase in the fetal incidence of traces of interventricular foramen/septum membranaceum in the heart, the biological relevance of this effect is unclear. Among an unexposed rat model system examining this biological phenomenon, alterations of the cardiac membranous ventricular septum were found to not affect postnatal survival and these alterations resolved spontaneously during neonatal life, suggesting a lack of toxicity associated with the presence of these membranous tissues (Solomon et al., 1997). As there were no other potential toxicologically relevant effects identified, the U.S. EPA did not identify a LOAEL. The reported concentrations of 0, 500, 2,510, and 10,000 mg/m^3^ correspond to HEC values of 0, 125, 627.5, and 2,500 mg/m^3^ for extrarespiratory effects.^5^

#### Carcinogenicity

No adequate inhalation carcinogenicity studies of isobutyl alcohol in animals have been identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

### 2.3.1 Genotoxicity

The genotoxicity potential for isobutyl alcohol has been evaluated in a limited number of in vitro and in vivo studies (see Table 4A for more details). Overall, the available data indicate that isobutyl alcohol is not a genotoxic agent.

Table 4A Summary of Isobutyl Alcohol Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References
Genotoxicity studies in prokaryotic organisms
Mutation | Salmonella typhimurium TA98, TA100, TA1535, TA1537 | 0, 10, 33.3, 100, 333, 1,000, 3,330, 5,000 μg/plate | − | − | Plate incorporation assay. No evidence of mutagenicity in any of the strains tested, with or without S9 activation. | American Cyanamid (1992)
Mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0.001–5 μL/plate | − | − | Plate incorporation assay. No evidence of mutagenicity in any of the strains tested, with or without S9 activation. | Litton Bionetics (1978a)
Mutation | S. typhimurium TA1535 | 0, 1 mg/plate | − | NDr | Ames assay. No evidence of mutagenicity. | Mirvish et al. (1993)
Mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 5, 10, 50, 100, 500, 1,000, 5,000 μg/plate | − | − | Preincubation assay. No evidence of mutagenicity in any of the strains tested, with or without S9 activation. | Shimizu et al. (1985)
Mutation | S. typhimurium TA97 TA98, TA100, TA1535, TA1537 | 0, 100, 333, 1,000, 3,333, 10,000 μg/plate, or to an upper dose defined by solubility | − | − | Preincubation assay. No evidence of mutagenicity in any of the strains tested, with or without rat and hamster S9 activation. | Zeiger et al. (1988)
Mutation | Escherichia coli WP2uvrA | 5, 10, 50, 100, 500, 1,000, 5,000 μg/plate | − | − | Ames assay. No evidence of mutagenicity with or without S9 activation. | Shimizu et al. (1985)
Mutation | Saccharomyces cerevisiae D4 | 0.001, 0.01, 0.1, 1.0, 5 μL/plate | − | − | Plate incorporation assay. No evidence of mutagenicity with or without S9 activation. | Litton Bionetics (1978a)
DNA damage (SOS induction) | S. typhimurium TL210 | NR | (+) | NDr | Luminescent umu microplate assay. TL210 is a phenotypic transformation of S. typhimurium TA1535 that contains a plasmid with luminescent genes LuxA-E extracted from Vibrio fischeri. Increased luminescence was observed using DMSO or methanol for dilution. The data table indicates that the finding was positive (defined as >twofold increase); however, the text indicates that the finding was “pseudopositive” (defined as 1.5–2-fold increase). | Nakajima et al. (2006)
DNA damage (SOS induction) | S. typhimurium TA1535/pSK1002 | NR | − | NDr | Light absorption umu test. Negative after a 4-h incubation using DMSO or methanol for dilution. | Nakajima et al. (2006)
Genotoxicity studies in mammalian cells—in vitro
Mutation | L5178Y mouse lymphoma cells | 0, 0.78, 1.56, 3.13, 6.25, 12.5 μL/mL (without activation) and 0, 0.39, 0.78, 1.56, 3.13, 6.25 μL/mL (with activation) | − | − | Forward mutation assay. No dose-related increase in mutation frequencies with or without S9 metabolic activation. Cytotoxicity was observed at >12.5 μL/mL with activation and at >3.13 and >6.25 μL/mL without activation, in two separate trials. Assays were conducted twice due to contamination issues in the first trial. | Litton Bionetics (1978b)
Mutation | V79 Chinese hamster fibroblasts | 0, up to 270 mM | − | − | HPRT assay. No genotoxicity was observed following a 2-h treatment with the test substance. The highest nontoxic concentration tested was 107 mM. | Kreja and Seidel (2002)
DNA damage | V79 Chinese hamster fibroblasts | 0, 53, 270 mM | − | NDr | Comet assay. No DNA damage was observed following a 4-h treatment with 53 mM; 270 mM was cytotoxic. | Kreja and Seidel (2002)
DNA damage | Human lung carcinoma epithelial A549 cells | 0, 53, 270 mM | − | NDr | Comet assay. A significant increase in DNA damage was only seen following a 4-h treatment with 270 mM. The cytotoxic IC50 was 11 mM; therefore, these results are considered negative (not tested below cytotoxic concentrations). | Kreja and Seidel (2002)
DNA damage | Primary human peripheral blood cells | 0, 53, 270 mM | − | NDr | Comet assay. No DNA damage was observed following a 4-h treatment with 53 mM; 270 mM was cytotoxic. | Kreja and Seidel (2002)
Clastogenicity (MN) | V79 Chinese hamster fibroblasts | 0, 11, 53 mM | − | NDr | MN were not induced following a 4-h treatment with the test substance. | Kreja and Seidel (2002)
Genotoxicity studies—mammalian species in vivo
Clastogenicity (CA) | White rats (8 M) were administered a single dose of isobutyl alcohol via gavage | 0, 40% aqueous solution equivalent to 1/5 LD50. | − | NA | Without activation, CAs in rat bone marrow cells 48-h after treatment were described by the study authors as “less pronounced” than alcohols with high molecular masses. The twofold increase in the rate of polyploid cells, 1.3-fold increase in cells with chromosome gaps, and 1.6% increase in cells with CAs were interpreted by OECD (2004) as negative. | Barilyak and Kozachuk (1988)
Clastogenicity (MN) | NMRI mice (M/F) were administered single oral doses of isobutyl alcohol via gavage | 0, 500, 1,000, 2,000 mg/kg | − | NA | No increase in polychromatic erythrocytes containing small or large MN after treatment. Positive controls (cyclophosphamide, vincristine) produced the expected response. | Engelhardt and Hoffmann (2000) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD (2004)

a (+) = weak positive, − = negative.

CA = chromosomal aberration; DMSO = dimethylsulfoxide; DNA = deoxyribonucleic acid; F = female(s); IC50 = half maximal inhibitory concentration; LD50 = median lethal dose; M = male(s); MN = micronuclei; NA = not applicable; NDr = not determined; NR = not reported.

Available in vitro studies indicate that isobutyl alcohol is not mutagenic to bacteria, yeast, or mammalian cells. Isobutyl alcohol was not mutagenic with or without metabolic activation in Salmonella typhimurium (Mirvish et al., 1993; American Cyanamid, 1992; Zeiger et al., 1988; Shimizu et al., 1985; Litton Bionetics, 1978a), Escherichia coli (Shimizu et al., 1985), or Saccharomyces cerevisiae (Litton Bionetics, 1978a). In a German study by Hilscher et al. (1969), available only from secondary sources (OECD, 2004; U.S. EPA, 1986), a sevenfold increase in reversions in E. coli CA274 cells was observed following a 72-hour incubation with 2.5% isobutyl alcohol. However, both secondary sources indicated that the methods were inadequate and considered the study unreliable; therefore, the study was not included in Table 4A. In mammalian cells, isobutyl alcohol was not mutagenic in mouse lymphoma cells or Chinese hamster fibroblasts, with or without metabolic activation (Kreja and Seidel, 2002; Litton Bionetics, 1978b).

Available in vitro studies also indicate that isobutyl alcohol is not clastogenic to mammalian cells, has a low potential to cause deoxyribonucleic acid (DNA) damage in bacteria, and does not induce DNA damage in mammalian cells. Isobutyl alcohol did not induce micronuclei (MN) in Chinese hamster fibroblasts, without metabolic activation (Kreja and Seidel, 2002). In a study that evaluated DNA damage in bacteria, the SOS response was assessed using the light absorption umu test and a more sensitive luminescent umu test in a recombinant S. typhimurium TA1535 strain (Nakajima et al., 2006). The SOS response was not increased using the light absorption test. Data reporting for the more sensitive luminescent test were inconsistent; isobutyl alcohol was reported as positive (>twofold increase in SOS response) in the data tables but “pseudopositive” (1.5–2-fold increase in SOS response) in the resulting discussion. Isobutyl alcohol did not induce DNA damage at noncytotoxic doses in human lung carcinoma epithelial A549 cells, V79 Chinese hamster fibroblasts, or primary human peripheral blood cells without metabolic activation (Kreja and Seidel, 2002).

In vivo studies were limited to two cytogenic studies, one with limited details in White rats and an Organisation for Economic Cooperation and Development (OECD) guideline mouse MN test in NMRI mice. In rats, there were slight increases (≤twofold) in the rate of bone marrow polyploid cells and in cells with chromosomal gaps or aberrations (Barilyak and Kozachuk, 1988). These increases were reported by the study authors to be less pronounced than those observed when testing other alcohols; OECD (2004) interpreted the results to be negative. No increases in the rates of polychromatic erythrocytes containing small or large MN were observed in mice administered single oral doses up to 2,000 mg isobutyl alcohol/kg (Engelhardt and Hoffmann, 2000 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD, 2004).

### 2.3.2 Supporting Human Toxicity Studies

Available supporting human inhalation studies are summarized in Table 4B and include a case report with insufficient details and two human studies evaluated as low confidence or uniformative during study evaluation due to major methodological limitations (see Appendix C for details).

Table 4B Other Studies

Test^a^ | Materials and Methods | Results | Comments | References
Supporting evidence—noncancer effects in humans following inhalation exposure
Case series report | Four laboratory workers occupationally exposed to unspecified levels of isobutyl alcohol for short periods up to 18 mo. | Vertigo, nausea, and headache were reported. There was one case of vestibular irritation and one case of Meniere’s disease. | This study is uninformative due to lack of available details. | Seitz (1972) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=999217) as cited in U.S. EPA (1986)
Occupational cohort study | Air sampling data from 12 exposed workers and 11 unexposed workers were collected to determine levels of exposure to multiple compounds.; Exposure was defined by department. Participants provided self-reported health surveys that included medical history, as well as sperm samples to examine for changes in spermatogenesis. | Exposure to isobutyl alcohol was negligible (below detection level for most participants). Therefore, no compound-specific analysis was performed. Health surveys found no abnormal effects on spermatogenesis, fertility, or liver or kidney function between exposed and control groups. | This study is uninformative regarding the potential effects of isobutyl alcohol on male reproductive toxicity (primary endpoint) or liver or kidney function due to negligible exposure. | Hollett and Aw (1982)
Skin irritation | In an acute patch test, a 25 µL volume of a 75% solution of isobutyl alcohol was applied to the skin of 12 participants of Asian descent, under occlusive conditions for 5 min. Prior to patch testing, subjects were preclassified as “flushers” (n = 8) or “nonflushers” (n = 4) when drinking alcohol. The sites were monitored for 60 min for signs of erythema. The conditions of a positive response were not defined. Reversibility was not evaluated. | A positive response was reported in 2/12 individuals. Both positive reactions were in individuals previously determined to have a predisposition for flushing.; Severity was not described. | This study is of limited usefulness due to multiple deficiencies, including short exposure duration and assessment time, short follow-up, subjective determination of results, no description of participant selection, and lack of discussion of confounding factors. | Wilkin and Stewart (1987); Wilkin and Fortner (1985)
Supporting evidence—noncancer effects in animals following inhalation exposure
Acute (mortality) | Acute toxicity data in rats were reported from RTECS database. | 4-h ALC = 4,000 ppm (12,126 mg/m^3^) | | Kennedy and Graepel (1991)
Acute (mortality) | Rats were exposed to isobutyl alcohol via inhalation. No additional study details were available. | LC_50_ = 19,200 mg/m^3^ | | Kushneva et al. (1983) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD (2004); IPCS (1987)
Acute (mortality) | Rats (6/group) were exposed to saturated isobutyl alcohol vapors reported to be approximately 16,000 ppm (49,248 mg/m^3^) for 2 h or to 8,000 ppm (24,624 mg/m^3^) for 4 h. | 100% survival at 49,248 mg/m^3^ for 2 h. Mortality in 2/6 rats at 24,624 mg/m^3^ for 4 h. | | Smyth et al. (1954) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS (1987)
Acute (mortality) | Female rats (6/group) were exposed to saturated vapors (estimated at 14,000 ppm or 42,441 mg/m^3^) of isobutyl alcohol for 2 or 4 h and were observed for 14 d. | All animals survived following a 2-h exposure. Mortality was 100% after a 4-h exposure. | | Mellon Institute (1986)
Acute (mortality) | Male and female rats (6/group) were exposed to an isobutyl alcohol concentration of 8,000 ppm (24,624 mg/m^3^) for 4 h. Male rats were tested twice (once with a sample from 1946 and once with a sample from 1953); females were tested once (sample NS). Mortality was recorded. | 1/6 male rats died following exposure to the 1953 sample; no mortalities following exposure to the 1946 sample.; No female mortalities. | | Mellon Institute (1986)
Acute (mortality) | Sprague Dawley rats (10/sex) were exposed to 6.5 mg/L (2,145 ppm) isobutyl alcohol vapors for 4 h. Animals were observed for 14 d following exposure. | 4-h LC_50_ >6,500 mg/m^3^; No deaths or signs or toxicity were observed. | | BASF (undated) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD (2004)
Acute (mortality) | Mice were exposed to isobutyl alcohol via inhalation. No additional study details were available. | LC_50_ = 15,500 mg/m^3^ | | Kushneva et al. (1983) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS (1987)
Acute (mortality) | Rabbits were exposed to isobutyl alcohol via inhalation. No additional study details were available. | LC_50_ = 26,250 mg/m^3^ | | Kushneva et al. (1983) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD (2004)
Acute (mortality) | Guinea pigs were exposed to isobutyl alcohol via inhalation. No additional study details were available. | LC_50_ = 19,900 mg/m^3^ | | Kushneva et al. (1983) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS (1987)
Acute (neurotoxicity) | Rats (10/sex/group) were exposed to isobutyl alcohol vapor concentrations of 1,500, 3,000, or 6,000 ppm (4,547, 9,095, or 18,189 mg/m^3^) for 6 h. Animals were observed for mortality and clinical signs of CNS depression. FOB and motor function tests were conducted prior to and immediately after exposure and on Days 1, 7, and 14 after dosing. At sacrifice (Day 15), animals were grossly examined, and central and peripheral nervous tissues were fixed for microscopic examination. | Rapid, but reversible general CNS depression occurred during exposure in the 3,000- and 6,000-ppm groups. Hypoactivity was observed at 1,500 ppm. At 6,000 ppm, females showed a decrease in alertness, and decreased motor activity was recorded in both sexes. One male exhibited an uncoordinated gait. All effects were transient. There were no treatment-related findings at gross necropsy. | | Monsanto (1994)
Acute (neurotoxicity) | Male albino SPF rats (4/group) were exposed whole body to at least three concentrations (NS) of isobutyl alcohol vapors for 4 h. A neurotropic effect was determined based on the inhibition of propagation and maintenance of an electrically evoked seizure. Baseline durations of hindlimb tonic extensions in response to 0.2-sec, 50-Hz, 180-V electrical impulses applied through ear electrodes were established prior to exposure. The effect of exposure on the duration of maximal tonic extension was measured. Each animal was tested up to 4 times with intervals of 3 wk between exposures. Experiments were performed in duplicate. Based on a linear regression, the concentration evoking a 30% depression in the duration of tonic extension (RC_30_) was determined. | Rat RC_30_ (30% depression of seizure activity) = 3,800 ppm (11,520 mg/m^3^); this is considered a sign of CNS depression. | | Frantík et al. (1994)
Acute (neurotoxicity) | Harlan Sprague Dawley rats (5/sex) were exposed to saturated isobutyl alcohol vapors for 6 h under semi-static conditions. Animals were observed for mortality and clinical signs and were necropsied 14 d following exposure. | No deaths were observed. Animals exhibited hypoactivity, lacrimation, narcosis, prostration, and abnormal breathing during exposure, and prostration, narcosis, and negative reflexes following exposure. | | Union Carbide Corp. (1993) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD (2004)
Acute (neurotoxicity) | Female H-strain mice (2/group) were exposed whole body to isobutyl alcohol vapors for 2 h. A neurotropic effect was determined based on the inhibition of propagation and maintenance of an electrically evoked seizure. Baseline durations of hindlimb tonic extensions in response to 0.2-sec, 50-Hz, 180-V electrical impulses applied through ear electrodes were established prior to exposure. The effect of exposure on the duration of maximal tonic extension was measured. Each animal was tested up to 4 times with intervals of 3 wk between exposures. Experiments were performed in duplicate. Based on a linear regression, the concentration evoking a 30% depression in the duration of tonic extension (RC_30_) was determined. | Mouse RC_30_ (30% depression of seizure activity) = 2,500 ppm (7,579 mg/m^3^); this is considered a sign of CNS depression. | | Frantík et al. (1994)
Acute (eye irritation) | Groups of male and female rats were exposed to isobutyl alcohol vapor concentrations of 2,000, 6,000, or 8,000 ppm (6,063, 18,189, or 24,252 mg/m^3^) for 6 h. Animals received ophthalmoscopic examinations at an unspecified time following exposure. | Inflammatory changes (iritis, vascular congestion, anterior synechia) were observed at ≥18,189 mg/m^3^. Inflammatory changes were accompanied by unilateral or bilateral corneal opacities, with the greatest severity at 24,252 mg/m^3^. | | Chemical Manufacturers Association (1994)
Acute (respiratory irritation) | Male Swiss OF^1^ mice (6/group) were exposed head only to four concentrations of isobutyl alcohol vapors for 5 min (concentrations NR). Respiratory rates were monitored and the concentration resulting in a 50% reduction in the breathing rate (RC_50_) was determined. | Mouse RD_50_ (50% decrease in respiratory rate) = 1,818 ppm (5,511 mg/m^3^); this is considered an indication of respiratory irritation. | | de Ceaurriz et al. (1981)
Acute (systemic) | Rats and rabbits were exposed to isobutyl alcohol concentrations of 100, 1,300, 8,000, or 15,700 mg/m^3^ via inhalation for 4 h. Animals were sacrificed 3 d later. Results were reported for both species together (no species-specific data). | Altered breathing frequency at ≥100 mg/m^3^; decreased number of lymphocytes at ≥1,300 mg/m^3^; airway irritation, hematological changes, and dystrophia of hepatocytes and olfactory neurons in the brain at ≥8,000 mg/m^3^; and similar but more severe effects at 15,700 mg/m^3^. | | Kushneva et al. (1983) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS (1987)
Short-term | Male CD rats (5/group) were exposed to 0, 2,274, 4,550, or 9,095 mg/m^3^ for 6 h/d, 5 d/wk for 2 wk. Animals were examined for changes in mortality, clinical signs (including subjective evaluations of response to external stimuli), food consumption, body weights, and hematological parameters.; Animals were subject to ophthalmoscopic examinations and FOB testing. Complete necropsies, organ weights, and histopathological analyses were done. | A marginal decrease in response to chamber wall tapping was observed during exposure starting at 2,274 mg/m^3^ with more pronounced effects at higher concentrations. General CNS depression and labored breathing occurred at the two higher exposure levels. | Observed CNS depression was transient and considered by the study authors to be due to acute exposure rather than an indication of neurotoxicity resulting from repeated exposures. | Kaempfe and Li (1996)
Subchronic | Rats (sex, strain, and number NS) were exposed to isobutyl alcohol vapor concentrations of 0.1, 0.5, or 3.0 mg/m^3^ continuously for 4 mo. | Reductions in erythrocyte numbers, hemoglobin content, cholinesterase, and catalase activity were reported at 0.5 and 3.0 mg/m^3^. At 3.0 mg/m^3^, there was an increased stimulus threshold to trigger avoidance response, and increased ALT and AST activities. | Data reporting was inadequate for independent analysis. | Tsulaya (1978) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD (2004)
Undefined duration | Mice (sex, strain, and number NS) were intermittently exposed to 2,125 ppm (6,442 mg/m^3^) of isobutyl alcohol for a total of 223 h (9.25 h/exposure). An additional group was also given repeated exposures to 6,400 ppm (19,400 mg/m^3^); duration of exposure for this group was NS. | No deaths were reported in the group exposed to 6,442 mg/m^3^ (no further details on this group). Transient narcosis was observed at 19,400 mg/m^3^. | Data reporting was inadequate for independent analysis. | Weese (1928) (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=999217) as cited in U.S. EPA (1986)
Supporting evidence—cancer effects in animals following oral exposure
Carcinogenicity | Male and female Wistar rats (19 in treatment group, 25 in control group; number per sex NS) were administered isobutyl alcohol via gavage at 0.2 mL/kg or 0.9% NaCl (control) twice/wk for a lifetime. | The average survival was 643 d for controls and 495 d for the treatment group. Three animals in the treatment group had malignant tumors (an antestomach carcinoma and a liver cell carcinoma, an antestomach carcinoma with myeloid leukemia, and myeloid leukemia). No tumors were reported in controls. Liver damage, including steatosis, necrosis, fibrosis, and cirrhosis, hyperplasia of blood forming tissues, and damage to heart tissue were also reported. | This study was uninformative. Overall, the study has major design and reporting deficiencies. Evidence was not presented clearly or transparently. Dosing frequency, animal number, and tumor incidences are too low to draw meaningful conclusions regarding the carcinogenic potential of isobutyl alcohol. | Dow Chemical (1992); Gibel et al. (1975)

a Acute = exposure for ≤24 hours; short term = repeated exposure for >24 hours ≤30 days; subchronic = repeated exposure for >30 days ≤10% life span (>30 days up to approximately 90 days in typically used laboratory animal species); chronic = repeated exposure for >10% life span for humans (more than approximately 90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002b).

ALC = approximate lethal concentration; ALT = alanine aminotransferase; AST = aspartate aminotransferase; CNS = central nervous system; FOB = functional observation battery; LC_50_ = median lethal concentration; NaCl = sodium chloride; NR = not reported; NS = not specified; RCx = concentration to cause x change in response (e.g., RC_30_ = concentration to cause 30% change in response); RTECS = Registry of Toxic Effects of Chemical Substances.

In a case-series report available only from a secondary source, vertigo, nausea, and headache were reported by workers occupationally exposed to isobutyl alcohol; no additional details regarding exposure levels or duration were available (Seitz, 1972 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=999217) as cited in U.S. EPA, 1986). In an occupational cohort study, sperm analysis, renal and liver function tests, and medical health survey reports of birth defects in offspring, infertility, miscarriages, and stillbirths were evaluated in workers exposed to a variety of chemicals; however, air sampling from potentially exposed factory workers indicated that exposure to isobutyl alcohol was negligible (Hollett and Aw, 1982). Therefore, no assessments of isobutyl alcohol were made in this study.

The only other available human studies both describe an acute patch test in 12 Asian volunteers; 8 of these volunteers were classified as “flushers” with a predisposition to skin redness when drinking alcohol (Wilkin and Stewart, 1987; Wilkin and Fortner, 1985). Subjects were dermally exposed to isobutyl alcohol for 5 minutes on presoaked skin. Results were reported as positive or negative for erythema (as opposed to a graded scoring system), but no clear definition of erythema was provided. Two of the volunteers, both “flushers,” were classified as positive. Overall, it can be concluded that a 5-minute exposure to isobutyl alcohol under the test conditions did not cause skin redness in most subjects and that the two subjects with redness were predisposed as described by the study authors, increasing the uncertainty surrounding results from these two individuals. However, the usefulness of this study is limited due to several deficiencies, including short exposure duration and assessment time, short follow-up, subjective determination of results, no description of participant selection, and lack of discussion of confounding factors.

### 2.3.3 Supporting Animal Toxicity Studies

Supporting animal toxicity studies include several acute and short-term inhalation studies, which indicate CNS depression and eye and respiratory irritation as toxicologically relevant effects following exposure to high air levels. Other supporting studies include a 4-month foreign language study in rats available only as a brief description in a secondary source and an inadequately reported developmental probe study in rats and rabbits. For carcinogenicity, the database is limited to an oral cancer study with methodological inadequacies and limited data reporting. See Table 4B for more details.

#### Supporting Studies for Noncarcinogenic Effects in Animals

Acute lethality studies on isobutyl alcohol indicate that isobutyl alcohol has relatively low lethality via the inhalation route. Reported median lethal concentration (LC_50_) values were 19,200 mg/m^3^ in rats, 15,500 mg/m^3^ in mice, 26,250 mg/m^3^ in rabbits, and 19,900 mg/m^3^ in guinea pigs (Kushneva et al., 1983 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD, 2004; Kushneva et al., 1983 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS, 1987; Mellon Institute, 1986). The acute exposure at which mortality first occurred (approximate lethal concentration [ALC]) for rats was reported as 12,126 mg/m^3^ (Kennedy and Graepel, 1991). Other lethality studies in rats reported no mortalities following exposure to saturated vapors (∼42,441–49,248 mg/m^3^) for 2 hours and 0, 33, and 100% mortality following a 4-hour exposure to 6,500, 24,624, and 42,441 mg/m^3^, respectively (BASF, undated (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD, 2004; Smyth et al., 1964 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS, 1987; Mellon Institute, 1986). In contrast, no deaths were reported in rats exposed to saturated vapors (estimated exposure not reported) for 6 hours (Union Carbide Corp., 1993 as cited in OECD, 2004). No mortalities were observed in mice following repeated exposure to 6,442 mg/m^3^ for a total of 223 hours (9.25 hours/exposure) (Weese, 1928 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=999217) as cited in U.S. EPA, 1986).

Neurotoxicity is the primary effect reported in available acute and short-term inhalation studies. Transient hypoactivity was reported at acute concentrations ≥4,547 mg/m^3^, with more pronounced CNS depression (e.g., decreased alertness, uncoordinated gait, prostration, narcosis) occurring at ≥7,579 mg/m^3^ (Frantík et al., 1994; Monsanto, 1994; Union Carbide Corp., 1993 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS, 1987). In an unpublished 2-week study in rats, transient decreases in response to stimuli (cage tapping) were observed during exposure to ≥2,274 mg/m^3^, with general CNS depression at ≥4,550 mg/m^3^; the effects ceased after the rats were removed from the chamber (Kaempfe and Li, 1996). A specialized study by Frantík et al. (1994) evaluated CNS depressant potential of isobutyl alcohol by evaluating inhibition of the propagation and maintenance of an electrically evoked seizure in rats and mice. The concentration required for a 30% decrease in seizure activity (RC_30_), measured by duration of hindlimb tonic extensions, in rats and mice was 11,520 and 7,579 mg/m^3^, respectively. One study, available only from a secondary source, reported dystrophia of olfactory neurons in the brain of rats and rabbits exposed to ≥8,000 mg/m^3^ for 4 hours (Kushneva et al., 1983 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS, 1987).

High air concentrations of isobutyl alcohol vapor are irritating to the eyes and airways. Exposure to isobutyl alcohol vapors for 6 hours resulted in inflammatory changes in the eye and corneal opacities in rats at ≥18,189 mg/m^3^ (Chemical Manufacturers Association, 1994). Respiratory irritation, indicated by altered breathing frequency, was reported in both rats and rabbits after exposure to ≥100 mg/m^3^ for 4 hours (Kushneva et al., 1983 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS, 1987). In another study, the 50% reduction in respiratory rates (RC_50_) in mice after 5 minutes of exposure to isobutyl alcohol vapors was 5,511 mg/m^3^ (de Ceaurriz et al., 1981). In the 2-week study by Kaempfe and Li (1996), labored breathing was reported during exposure to concentrations ≥4,550 mg/m^3^; effects ceased upon removal from the chamber.

One acute inhalation study, available only from a secondary source, reported hematological changes, dystrophia of hepatocytes, and a reduced number of lymphocytes in both rats and rabbits exposed to ≥1,300 mg/m^3^ for 4 hours (Kushneva et al., 1983 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=1579867) as cited in IPCS, 1987). No further details on these effects are available.

In a foreign-language study available only from a secondary source, transient narcosis was observed in mice following repeated exposures to 19,400 mg/m^3^ (number and duration of exposures not reported) (Weese, 1928 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=999217) as cited in U.S. EPA, 1986). In a foreign-language subchronic study also available only from a secondary source, leg withdrawal response to electrical stimuli was depressed in rats exposed for 4 months to 3.0 mg/m^3^ (Tsulaya, 1978 (https://heronet.epa.gov/heronet/index.cfm?action=search.view&reference_id=5097684) as cited in OECD, 2004). Minor hematological changes (reduced hemoglobin content, decreased erythrocyte count) and increased serum ALT and AST were also reported at ≥0.5 mg/m^3^. No effects were observed at 0.1 mg/m^3^. Available data from these studies are too limited for independent analysis.

#### Supporting Studies for Developmental Effects in Animals

No supporting studies for developmental effects in animals have been identified. The literature search did identify a technical report (Eastman Kodak, 1992) that, upon analysis, was found to be the same study as the Klimisch and Hellwig (1995) study.

#### Supporting Studies for Carcinogenic Effects in Animals

Data on the carcinogenic potential for isobutyl alcohol are limited to a single foreign language study by Gibel et al. (1975), with an English translation by Dow Chemical (1992). In this study, 19 male and female rats (number per sex not specified) were administered isobutyl alcohol at 0.2 mL/kg via gavage twice weekly until natural death. Twenty-five male and female controls were similarly treated with 0.9% sodium chloride (NaCl). Three animals in the treated group had malignant tumors (an antestomach carcinoma and a liver cell carcinoma, an antestomach carcinoma with myeloid leukemia, and myeloid leukemia). No tumors were reported in the controls. This study was evaluated as critically deficient (uninformative) during systematic review because of its limited reporting and several methodological inadequacies (e.g., inadequate dosing frequency, animal number, and tumor incidences); see Appendix C for more details.

### 2.3.4 Metabolism/Toxicokinetic Studies

The toxicokinetic properties of isobutyl alcohol have been evaluated in a limited number of published studies, and also reviewed by OECD (2004), IPCS (1987), and U.S. EPA (1986); these secondary sources cite a number of foreign language studies and unpublished data sources that were not available for independent review. An overview based both on published studies and these reviews is presented below.

#### Absorption

Isobutyl alcohol is readily absorbed through the lungs and gastrointestinal tract and is expected to be readily absorbed through the skin, consistent with general principles associated with the identified physicochemical properties. Experimental data in rats show rapid absorption of isobutyl alcohol based on detection of the parent compound and isobutyl alcohol metabolites in the blood within 5 minutes of inhalation exposure (OECD, 2004; IPCS, 1987; U.S. EPA, 1986). Peak blood concentrations of isobutyl alcohol were observed 15 minutes after inhalation exposure in rats (OECD, 2004). The blood-air partition coefficient for isobutyl alcohol was determined to be 541–578 in humans and 880 in rats (Kaneko et al., 1994; Fiserova-Bergerova and Diaz, 1986); see Table 5. Experimental data from humans and laboratory animals indicate that isobutyl alcohol is also rapidly absorbed through the gastrointestinal tract based on detection of the parent compound and isobutyl alcohol metabolites in the blood and urine <1 hour after oral administration (OECD, 2004; U.S. EPA, 1986). In humans, blood levels of isobutyl alcohol peak 45–120 minutes after the start of oral exposure (OECD, 2004). Similarly, peak blood levels in rabbits were observed 1 hour after oral administration (U.S. EPA, 1986). No in vivo dermal studies measuring absorption of isobutyl alcohol have been identified; however, dermal absorption was computationally predicted to be high following direct dermal contact with isobutyl alcohol liquid or vapors (Fiserova-Bergerova et al., 1990).

Table 5 Partition Coefficients for Isobutyl Alcohol

Species | Muscle | Kidney | Lung | Brain | Fat | Liver | Blood | Reference
Tissue-gas partition coefficients for isobutyl alcohol
Human | 343 ± 46 | 371 ± 28 | 400 ± 42 | White matter: 337 ± 57; Gray matter: 387 ± 29 | 388 ± 33 | NDr | 541 ± 134 | Fiserova-Bergerova and Diaz (1986)
Human | NDr | NDr | NDr | NDr | NDr | NDr | 578 ± 75 | Kaneko et al. (1994)
Rat | 850 ± 66 | 875 ± 42 | NDr | 868 ± 22 | 720 ± 52 | 880 ± 100 | 880 ± 37 | Kaneko et al. (1994)
Tissue-blood partition coefficients for isobutyl alcohol
Rat (measured) | 0.97 | 0.99 | NDr | 0.99 | 0.82 | 1.00 | NA | Kaneko et al. (1994)
Human (predicted) | 0.38–0.76 | 0.41–0.82 | 0.45–0.88 | 0.43–0.85 | 0.43–0.85 | NDr | NA | Poulin and Krishnan (1995)

NA = not applicable; NDr = not determined.

#### Distribution

Data regarding distribution of isobutyl alcohol or its metabolites to specific tissues following in vivo exposure were not available. In a developmental toxicity study, Klimisch and Hellwig (1995) stated that isobutyl alcohol is distributed to both hydrophilic and lipophilic compartments, but did not cite the source of this information. It is assumed that isobutyl alcohol in blood can cross the placental barrier, but no specific data to test this hypothesis were available. Tissue-gas and tissue-blood coefficients have been determined experimentally in rat tissues, and tissue-blood coefficients have been predicted in human tissues (Poulin and Krishnan, 1995; Kaneko et al., 1994) (see Table 5).

#### Metabolism

The primary metabolites identified in blood and urine in humans and laboratory animals following exposure include isobutyraldehyde and isobutyric acid (OECD, 2004; U.S. EPA, 1986). Metabolism is rapid, with peak metabolite concentrations in blood observed at 2–4 hours after the start of oral dosing in humans and 25 minutes after the start of inhalation exposure in rats (OECD, 2004). Other urinary metabolites identified include acetaldehyde, acetic acid, and unspecified glucuronic acid conjugates (OECD, 2004; IPCS, 1987; U.S. EPA, 1986). Metabolism may be dose-dependent because aldehydes were only observed in rabbits following exposure to drinking water saturated with isobutyl alcohol, but not to single gavage doses of ∼618–1,600 mg/kg (U.S. EPA, 1986). Isovaleric acid was also identified in the urine of rabbits following exposure to drinking water saturated with isobutyl alcohol; however, this unexplainable metabolite may have been identified in error because of potential co-elution of a metabolite with isovaleric acid on the chromatogram (OECD, 2004).

Based on identified metabolites in blood and urine following exposure to isobutyl alcohol, it is proposed that isobutyl alcohol is oxidized into isobutyraldehyde by alcohol dehydrogenase (ADH), which is further oxidized into isobutyric acid via aldehyde dehydrogenases (ALDH) (OECD, 2005; U.S. EPA, 1986). Subsequently, isobutyric acid reacts with Coenzyme A (CoA), enters the tricarboxylic acid cycle, and results in liberation of carbon dioxide (CO_2_) (U.S. EPA, 1986). ADH inhibition studies confirm the primary role of ADH in isobutyl alcohol oxidation. Using the ADH inhibitors, 4-methylpyrazole and isobutyramide, Plapp et al. (2015) estimated that ADH is responsible for approximately 66% of isobutyl alcohol metabolism in vivo in rats. Pyrazole, another ADH inhibitor, was also effective at reducing breakdown of isobutyl alcohol by approximately 50% (Lester and Benson, 1970). ADH metabolism is rapid in both in situ rat liver perfusions and in vitro rat liver homogenates (2–7 µmol/g liver/minute) (OECD, 2005; U.S. EPA, 1986). Based on in vitro studies with human liver Class I, II, and III ADHs, Class I ADH isoenzymes are the most active for isobutyl alcohol (Ehrig et al., 1988). Human skin ADH enzymes also have demonstrated the ability to oxidize isobutyl alcohol (Wilkin and Stewart, 1987).

#### Excretion

Excretion of isobutyl alcohol and its metabolites is primarily via urine, with small amounts of unchanged isobutyl alcohol and CO_2_ in expired air (OECD, 2005; IPCS, 1987; U.S. EPA, 1986). Blood and urine samples collected from humans who were administered approximately 5 mg/kg isobutyl alcohol in an ethanol/water mixture over a 2-hour time period indicated rapid elimination of unchanged isobutyl alcohol and its primary metabolites in urine (OECD, 2004). Urinary levels of isobutyl alcohol, isobutyraldehyde, and isobutyric acid peaked 1, 8, and 2 hours after the start of oral exposure in humans, respectively (OECD, 2004). Isobutyl alcohol was no longer detected in the blood of humans 12 hours after drinking an orange juice, isobutyl alcohol, and ethanol mixture, although ethanol consumption likely altered toxicokinetics (U.S. EPA, 1986). Excretion of ^14^CO_2_ in expired air was used to determine an excretion rate of 6.9 mmol/kg-hour in rats following an intraperitoneal (i.p.) injection of 6.8 mmol/kg of [^14^C]-labelled isobutyl alcohol (Lester and Benson, 1970). Another study in rats determined a first-order elimination rate of 3.8 ± 0.5 mmol/kg-hour following an i.p. injection of 1 M isobutyl alcohol (Plapp et al., 2015). Clearance of isobutyl alcohol from blood following intravenous (i.v.) exposure is 0.13 L/kg-minute in rats (Kielbasa and Fung, 2000).

1 HEC calculated by treating isobutyl alcohol as a Category 3 gas (based on the lack of respiratory effects and the ability of similar alcohols to produce systemic effects when inhaled) using the following equation from the U.S. EPA (1994) methodology: HEC_ER_ = exposure level (mg/m^3^) × (hours/day exposed ÷ 24 hours) × (days/week exposed ÷ 7 days) × ratio of blood-gas partition coefficient (animal:human), using a default coefficient of 1 because the rat blood-air partition coefficient of 880 is greater than the range of 541–578 reported for human blood-air partition coefficients according to Kaneko et al. (1994) and Fiserova-Bergerova and Diaz (1986).

2 HEC calculated by treating isobutyl alcohol as a Category 3 gas (based on the lack of respiratory effects and the ability of similar alcohols to produce systemic effects when inhaled) and using the following equation from the U.S. EPA (1994) methodology: HEC_ER_ = exposure level (mg/m^3^) × (hours/day exposed ÷ 24 hours) × (days/week exposed ÷ 7 days) × ratio of blood-gas partition coefficient (animal:human), using a default coefficient of 1 because the rat blood-air partition coefficient of 880 is greater than the range of 541–578 reported for human blood-air partition coefficients according to Kaneko et al. (1994) and Fiserova-Bergerova and Diaz (1986).

3 HEC calculated by treating isobutyl alcohol as a Category 3 gas (based on the lack of respiratory effects and the ability of similar alcohols to produce systemic effects when inhaled) and using the following equation from the U.S. EPA (1994) methodology: HEC_ER_ = exposure level (mg/m^3^) × (hours/day exposed ÷ 24 hours) × (days/week exposed ÷ 7 days) × ratio of blood-gas partition coefficient (animal:human), using a default coefficient of 1 because the rat blood-air partition coefficient of 880 is greater than the range of 541–578 reported for human blood-air partition coefficients according to Kaneko et al. (1994) and Fiserova-Bergerova and Diaz (1986).

4 HEC calculated by treating isobutyl alcohol as a Category 3 gas (based on the lack of respiratory effects and the ability of similar alcohols to produce systemic effects when inhaled) and using the following equation from the U.S. EPA (1994) methodology: HEC_ER_ = exposure level (mg/m^3^) × (hours/day exposed ÷ 24 hours) × (days/week exposed ÷ 7 days) × ratio of blood-gas partition coefficient (animal:human), using a default coefficient of 1 because the rat blood-air partition coefficient of 880 is greater than the range of 541–578 reported for human blood-air partition coefficients according to Kaneko et al. (1994) and Fiserova-Bergerova and Diaz (1986).

5 HEC calculated by treating isobutyl alcohol as a Category 3 gas (based on the lack of respiratory effects and the ability of similar alcohols to produce systemic effects when inhaled) and using the following equation from the U.S. EPA (1994) methodology: HEC_ER_ = exposure level (mg/m^3^) × (hours/day exposed ÷ 24 hours) × (days/week exposed ÷ 7 days) × ratio of blood-gas partition coefficient (animal:human), using a default coefficient of 1 because the blood-air partition coefficient for isobutyl alcohol in rabbits has not been determined. The human blood-air partition coefficient ranges between 541 and 578 according to Kaneko et al. (1994) and Fiserova-Bergerova and Diaz (1986).