# 1 INTRODUCTION

2-Methyl-1-propanol (isobutyl alcohol), CASRN 78-83-1, is one of four possible butanols of 4-carbon alcohol isomers. The other three butanols are 1-butanol, 2-butanol, and tert-butyl alcohol (Billig, 2001). Isobutyl alcohol is used as a solvent or as an intermediate in the flavor, fragrance, pharmaceutical, and pesticide industries. Other reported uses of isobutyl alcohol are as a process solvent (replacement for 1-butanol); a diluent and additive for nitrocellulose and synthetic resins and lacquers; a solvent in paint strippers, cleaners, hydraulic fluids, and wetting agents; and a component of printing inks and related products (NLM, 2019; Hahn et al., 2013; Billig, 2001). Isobutyl alcohol is listed on the U.S. EPA’s Toxic Substances Control Act (TSCA) public inventory (U.S. EPA, 2021), and it is registered with Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (ECHA, 2019).

The primary isobutyl alcohol production method is through propene hydroformylation, in which carbon monoxide and hydrogen are added to propene in the presence of catalysts. Selection of the catalyst and manufacturing processes determines the ratio of isobutyl alcohol produced compared to other isomers. Rhodium has been found to be a more favorable catalyst when optimizing the reaction for isobutyraldehyde, the isobutyl alcohol precursor. Another commercial production method of isobutyl alcohol is the Reppe process in which olefins, carbon monoxide, and water react in the presence of a catalyst. Isobutyl alcohol occurs in natural products and can be isolated from fusel oils (Hahn et al., 2013).

The empirical formula for isobutyl alcohol is C_4_H_10_O and its structure is shown in Figure 1. Table 1 summarizes the physicochemical properties of isobutyl alcohol. Isobutyl alcohol is a clear, colorless liquid at environmental temperatures with a high vapor pressure and high water solubility. Volatilization of isobutyl alcohol from water and moist surfaces is expected based on a measured Henry’s law constant of 9.78 × 10^−6^ atm-m^3^/mol. Hydrolysis of isobutyl alcohol in aqueous conditions is not expected based upon the chemical structure, which lacks functional groups that hydrolyze under environmental conditions. Adsorption of isobutyl alcohol to suspended solids and sediment in water is not expected based on its estimated soil adsorption coefficient (K_oc_) of 10.3 L/kg. Volatilization of isobutyl alcohol from dry surfaces is also expected based on its measured vapor pressure. In the atmosphere, isobutyl alcohol will exist solely as a vapor, where it will be degraded by reaction with photochemically produced hydroxyl radicals corresponding to a half-life of 1.7 days. Direct photolysis is not expected because isobutyl alcohol does not contain chromophores that absorb at wavelengths >290 nm (wavelengths necessary for sunlight photolysis). Isobutyl alcohol is expected to have high mobility in soil based on its soil adsorption coefficient (estimated K_oc_ of 10.3 L/kg), which indicates that it may leach to groundwater.

Figure 1 Isobutyl Alcohol (CASRN 78-83-1) Structure

Chemical structure diagram for Isobutanol

Table 1 Physicochemical Properties of Isobutyl Alcohol (CASRN 78-83-1)

Property (unit) | Value
Physical state | Liquid^a^
Boiling point (°C) | 108^b^
Melting point (°C) | −108^b^
Density (g/cm^3^) | 0.822^b^ (predicted average)
Vapor pressure (mm Hg) | 10.4^b^
pH (unitless) | NV
Acid dissociation constant (pKa) (unitless) | NV
Solubility in water (mol/L) | 1.12^b^
Octanol-water partition coefficient (log K_ow_) | 0.760^b^
Henry’s law constant (atm-m^3^/mole) | 9.78 × 10^−6^ ^b^
Soil adsorption coefficient (K_oc_) (L/kg) | 10.3^c^ (predicted average)
Atmospheric OH rate constant (cm^3^/molecule-sec) | 1.17 × 10^−11^ ^b^
Atmospheric half-life (d) | 1.7 (calculated based on the measured OH rate constant)^b^
Relative vapor density (air = 1) | 2.56^c^
Molecular weight (g/mol) | 74.123^b^
Flash point (closed cup in °C) | 28.6^b^ (predicted average)

a O’Neil (2013).

b Data were extracted from the U.S. EPA CompTox Chemicals Dashboard (2-methyl-1-propanol; CASRN 78-83-1; https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID0021759; accessed December 15, 2021). All listed values represent experimentally determined averages unless otherwise noted.

c NLM (2019).

NV = not available; U.S. EPA = U.S. Environmental Protection Agency.

A summary of available toxicity values for isobutyl alcohol from the U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Toxicity Values for Isobutyl Alcohol (CASRN 78-83-1)

Source (parameter)^a,^ ^b^ | Value (applicability) | Notes | Reference^c^
Noncancer
IRIS (RfD) | 0.3 mg/kg-d | Based on hypoactivity and ataxia in rats exposed orally for 13 wk | U.S. EPA (2002a)
HEAST (sRfD) | 3 mg/kg-d | Based on hypoactivity and ataxia in rats exposed orally for 13 wk | U.S. EPA (2011)
DWSHA | NV | NA | U.S. EPA (2018)
ATSDR | NV | NA | ATSDR (2019)
IPCS | NV | NA | IPCS (1987)
CalEPA | NV | NA | CalEPA (2020); CalEPA (2019)
OSHA (PEL) | 100 ppm (300 mg/m^3^) | 8-h TWA for general industry, construction, and shipyard employment | OSHA (2020); OSHA (2018a); OSHA (2018b)
NIOSH (REL) | 50 ppm (150 mg/m^3^) | 10-h TWA | NIOSH (2018)
NIOSH (IDLH) | 1,600 ppm | Based on acute inhalation toxicity data in rats | NIOSH (1994)
ACGIH (TLV) | 50 ppm | 8-h TWA based on skin and eye irritation | ACGIH (2018); ACGIH (2001)
USAPHC (air-MEG) | 1-h critical: 5,000 mg/m^3^; 1-h marginal: 5,000 mg/m^3^; 1-h negligible: 3,500 mg/m^3^; 8-h negligible: 150 mg/m^3^; 14-d negligible: 52 mg/m^3^; 1-yr negligible: 52 mg/m^3^ | 1-h values based on TEELs; 8-h,14-d, and 1-yr values based on ACGIH TLV for eye and skin irritation | U.S. APHC (2013)
Cancer
IRIS | NV | NA | U.S. EPA (2002a)
HEAST | NV | NA | U.S. EPA (2011)
DWSHA | NV | NA | U.S. EPA (2018)
NTP | NV | NA | NTP (2016)
IARC | NV | NA | IARC (2019)
CalEPA | NV | NA | CalEPA (2020); CalEPA (2019)
ACGIH | NV | NA | ACGIH (2018)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; USAPHC = U.S. Army Public Health Command.

b Parameters: IDLH = immediately dangerous to life or health concentrations; MEG = military exposure guideline; PEL = permissible exposure level; REL = recommended exposure level; RfD = reference dose; sRfD = subchronic reference dose; TEEL = temporary emergency exposure limit; TLV = threshold limit value; TWA = time-weighted average.

c Reference date is the publication date for the database and not the date the online source was accessed.

NA = not applicable; NV = not available.

Systematic review methods were used to identify studies relevant to the derivation of inhalation provisional toxicity values and oral and inhalation cancer weight of evidence (WOE) for isobutyl alcohol, CASRN 78-83-1. Details and results of systematic literature review can be found in Appendix B.