# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2001). Isobutanol. In Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH.
ACGIH (American Conference of Governmental Industrial Hygienists). (2018). Isobutanol. In 2018 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
American Cyanamid (American Cyanamid Company). (1992). Mutagenicity Test on Ct-516-92 in the Salmonella/mammalian-microsome Reverse Mutation Assay (Ames Test): Final Report with Cover Letter dated 121592. (EPA/OTS; Doc #88-930000082).
ATSDR (Agency for Toxic Substances and Disease Registry). (2019). Toxic substances portal: Toxicological profiles. Atlanta, GA. http://www.atsdr.cdc.gov/toxprofiles/index.asp
Barilyak IR; Kozachuk SY. (1988). Investigation of the cytogenetic effect of a number of monohydric alcohols on rat bone marrow cells. Cytology and Genetics 22: 51–54.
Billig E. (2001). Butyl alcohols. In Kirk-Othmer Encyclopedia of Chemical Technology (4th, Online ed.). New York, NY: John Wiley & Sons. 10.1002/0471238961.0221202502091212.a01.pub2
Branch DK; Kaempfe TA; Thake DC; Li AA. (1996). Three month neurotoxicity study of isobutanol administered by whole-body inhalation to CD rats, with cover letter dated 3/14/96 [TSCA Submission]. (EHA 94075. OTS0558854. 44624). Arlington, VA: Chemical Manufacturers Association. Monsanto. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0558854.xhtml
CalEPA (California Environmental Protection Agency). (2019). OEHHA chemical database. Sacramento, CA: Office of Environmental Health Hazard Assessment. Retrieved from https://oehha.ca.gov/chemicals
CalEPA (California Environmental Protection Agency). (2020). Consolidated table of OEHHA/ARB approved risk assessment health values (May 8, 2018 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
Chemical Manufacturers Association. (1994). Initial Submission: Letter from Chem Mfgs Assn to USEPA Regarding Acute Inhalation Neurotoxicity Probe Study on Isobutyl Alcohol in Rats dated 030894. (EPA/OTS; Doc #88-940000163).
Crissman JW; Goodman DG; Hildebrandt PK; Maronpot RR; Prater DA; Riley JH; Seaman WJ; Thake DC. (2004). Best practices guideline: Toxicologic histopathology. Toxicol Pathol 32: 126–131. 10.1080/01926230490268756 14713558
de Ceaurriz JC; Micillino JC; Bonnet P; Guenier JP. (1981). Sensory irritation caused by various industrial airborne chemicals. Toxicol Lett 9: 137–143. 10.1016/0378-4274(81)90030-8 7302985
Dow Chemical (Dow Chemical Company). (1992). Initial submission: Experimental investigation of carcinogenic effects of solvents exemplified by 1-propanol, 2-methyl-1-propanol & 3-methyl-1-butanol with cover letter 012092 [TSCA Submission]. (EPA/OTS Doc #88-920000695; 8EHQ-0192-2049). Midland, MI: U.S. Environmental Protection Agency. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0533858.xhtml
Eastman Kodak (Eastman Kodak Company). (1992). Initial submission: Letter from Eastman Kodak Company to USEPA submitting information concerning the prenatal toxicity of 2-methyl-1-propanol in rabbits after inhalation [TSCA Submission]. (EPA/OTS Doc #88-920000750). https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0533907.xhtml
ECHA (European Chemicals Agency). (2019). 2-methylpropan-1-ol: Registration dossier. Available online at https://echa.europa.eu/registration-dossier/-/registered-dossier/15092 (accessed May 9, 2019).
Ehrig T; Bohren KM; Wermouth B; von Wartburg JP. (1988). Degradation of aliphatic alcohols by human liver alcohol dehydrogenase: Effect of ethanol and pharmacokinetic implications. Alcohol Clin Exp Res 12: 789–794. 10.1111/j.1530-0277.1988.tb01347.x 3064640
Fiserova-Bergerova V; Diaz ML. (1986). Determination and prediction of tissue-gas partition coefficients. Int Arch Occup Environ Health 58: 75–87. 10.1007/BF00378543 3721592
Fiserova-Bergerova V; Pierce JT; Droz PO. (1990). Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17: 617–635. 10.1002/ajim.4700170507 2337085
Frantík E; Hornychová M; Horváth M. (1994). Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66: 173–185. 10.1006/enrs.1994.1053 8055839
Gibel W; Lohs KH; Wildner GP. (1975). [Experimental study on cancerogenic activity of Propanol-1, 2-Methylpropanol-1 and 3-Methylbutanol-1 (author's transl)]. Arch Geschwulstforsch 45: 19–24.168833
Hahn HD; Dämbkes G; Rupprich N; Bahl H; Frey GD. (2013). Butanols. In Ullmann's Encyclopedia of Industrial Chemistry (7th ed.). New York, NY: John Wiley & Sons.
Hilscher H; Geissler E; Lohs K; Gibel W. (1969). [Toxicity and mutagenicity of single fusel oil components on E. coli]. Acta Biol Med Ger 23: 843–852.4912423
Hollett BA; Aw TC. (1982). Health Hazard Evaluation Report No. HETA-80-228-1241, Edwin Cooper Company, Sauget, Illinois. (Health Hazard Evaluation Report No. HETA-80-228-1241). Cincinnati, Ohio: Hazard Evaluations and Technical Assistance Branch, NIOSH, U.S. Department of Health and Human Services. https://www.cdc.gov/niosh/nioshtic-2/00178930.html
IARC (International Agency for Research on Cancer). (2019). Agents classified by the IARC monographs. Lyon, France. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf
IPCS (International Programme on Chemical Safety). (1987). Environmental health criteria for isobutanol [WHO EHC]. In Environmental health criteria 65: Butanols: Four isomers: 1-butanol, 2-butanol, tert-butanol, isobutanol. http://www.inchem.org/documents/ehc/ehc/ehc65.htm
Kaempfe TA; Li AA. (1996). Exposure concentration range-finding study for a subchronic inhalation neurotoxicity study of isobutanol administered by whole-body inhalation to cd rats, w/cvr ltr dated 3/14/96 [TSCA Submission]. (EPA/OTS: Doc #44624). Washington, DC: Monsanto Company. Chemical Manufacturers Association. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0558856
Kaneko T; Wang PY; Sato A. (1994). Partition coefficients of some acetate esters and alcohols in water, blood, olive oil, and rat tissues. Occup Environ Med 51: 68–72. 10.1136/oem.51.1.68 8124468
Kennedy GL Jr; Graepel GJ. (1991). Acute toxicity in the rat following either oral or inhalation exposure. Toxicol Lett 56: 317–326. 10.1016/0378-4274(91)90160-8 2035177
Kielbasa W; Fung HL. (2000). Pharmacokinetics of a model organic nitrite inhalant and its alcohol metabolite in rats. Drug Metab Dispos 28: 386–391.10725305
Klimisch HJ; Hellwig J. (1995). Studies on the prenatal toxicity of 3-methyl-1-butanol and 2-methyl-1-propanol in rats and rabbits following inhalation exposure. Toxicol Sci 27: 77–89. 10.1093/toxsci/27.1.77
Kreja L; Seidel HJ. (2002). Evaluation of the genotoxic potential of some microbial volatile organic compounds (MVOC) with the comet assay, the micronucleus assay and the HPRT gene mutation assay. Mutat Res 513: 143–150.11719099
Lester D; Benson GD. (1970). Alcohol oxidation in rate inhibited by pyrazole, oximes, and amides. Science 169: 282–283.5430990
Li AA; Kaempfe TA. (1996). Three month schedule controlled operant behavior study of isobutanol by whole body inhalation to CD rats, with cover letter dated 3/14/96. (OTS0558855. 44624. 42142/42134G F8-9). Monsanto Company. Chemical Manufacturers Association.
Li AA; Thake DC; Kaempfe TA; Branch DK, O’Donnell P.; Speck FL; Tyler TR; Faber WD; Jasti SL; Ouellette R; Banton MI. (1999). Neurotoxicity evaluation of rats after subchronic inhalation exposure to isobutanol. Neurotoxicology 20: 889–900.10693970
Litton Bionetics. (1978a). Mutagenicity evaluation of isobutanol alcohol in the ames salmonella/microsome plate test (final report) with cover letter dated 031187 (pp. 13).
Litton Bionetics. (1978b). Mutagenicity evaluation of isobutyl alcohol in the mouse lymphoma forward mutation assay (final report) with cover letter dated 031187. (EPA/OTS; Doc #86870000236). New York, NY: Celanese Chemical Company.
Mellon Institute (Mellon Institute of Industrial Research). (1986). Range finding tests on isobutanol with cover letter dated 050286 [TSCA Submission]. (EPA/OTS Doc #878216453). Dansbury, CT: Union Carbide Corporation. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0510381
Mirvish SS; Williamson J; Babcook D; Chen SC. (1993). Mutagenicity of iso-butyl nitrite vapor in the Ames test and some relevant chemical properties, including the reaction of iso-butyl nitrite with phosphate. Environ Mol Mutagen 21: 247–252. 10.1002/em.2850210307 8462528
Monsanto (Monsanto Company). (1994). Acute neurotoxicity study of isobutanol in Sprague-Dawley rats, with cover letter dated 9/28/94 [TSCA Submission]. (EPA/OTS Doc #44614). Washington, DC: Chemical Manufacturers Association. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0558834.xhtml
Nakajima D; Ishii R; Kageyama S; Onji Y; Mineki S; Morooka N; Takatori K; Goto S. (2006). Genotoxicity of microbial volatile organic compounds. J Health Sci 52: 148–153. 10.1248/jhs.52.148
Nemec MD. (2003). Final report: Volume 1 of 10 (Text and summary tables 1-124). An inhalation two-generation reproductive toxicity study of isobutanol in rats. (WIL-186013. 89040000059. 8EHQ-03-15213B). WIL Research Laboratories, Inc. Oxo Process Panel of the American Chemistry Council. https://chemview.epa.gov/chemview/proxy?filename=2003-12-8EHQ-03-15213B_8ehq_1203_15213b.pdf
NIOSH (National Institute for Occupational Safety and Health). (1994). Immediately Dangerous to Life or Health Concentrations (IDLH): Isobutyl alcohol. Available online at https://www.cdc.gov/niosh/idlh/78831.html (accessed June 6, 2019).
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards: Isobutyl alcohol. Cincinnati, OH. https://www.cdc.gov/niosh/npg/npgd0352.html
NLM (National Library of Medicine). (2019). HSDB Annotation Record: Isobutyl alcohol. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/49
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
O'Neil MJ. (2013). Isobutyl alcohol. In O'Neil MJ (Ed.), The Merck Index: An encyclopedia of chemicals, drugs, and biologicals (15th ed.). Cambridge, UK: Royal Society of Chemistry.
OECD (Organisation for Economic Co-operation and Development). (2004). Isobutanol. CAS Number: 78-83-1. SIDS initial assessment report for SIAM 19. Berlin, Germany. https://hpvchemicals.oecd.org/ui/handler.axd?id=C215E862-45FB-4A03-8643-85155A519C6B
OECD (Organisation for Economic Co-operation and Development). (2005). Isobutanol. In Screening Information Data Set for High Production Volume Chemicals.
OSHA (Occupational Safety & Health Administration). (2018a). Air contaminants: Occupational safety and health standards for shipyard employment, Subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC: U.S. Department of Labor. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2018b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, Subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992 (accessed June 6, 2019).
OSHA (Occupational Safety & Health Administration). (2020). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
Plapp BV; Leidal KG; Murch BP; Green DW. (2015). Contribution of liver alcohol dehydrogenase to metabolism of alcohols in rats. Chem Biol Interact 234: 85–95. 10.1016/j.cbi.2014.12.040 25641189
Poulin P; Krishnan K. (1995). A biologically-based algorithm for predicting human tissue: Blood partition coefficients of organic chemicals. Hum Exp Toxicol 14: 273–280. 10.1177/096032719501400307 7779458
Shimizu H; Suzuki Y; Takemura N; Goto S; Matsushita H. (1985). The results of microbial mutation test for forty-three industrial chemicals. Sangyo Igaku 27: 400–419.3913787
Solomon HM; Wier PJ; Fish CJ; Hart TK; Johnson CM; Posobiec LM; Gowan CC; Maleeff BE; Kerns WD. (1997). Spontaneous and induced alterations in the cardiac membranous ventricular septum of fetal, weanling, and adult rat. Teratology 55: 185–194. 10.1002/(SICI)1096-9926(199703)55:3<185::AID-TERA3>3.0.CO;2-1 9181672
U.S. APHC (U.S. Army Public Health Command). (2013). Environmental health risk assessment and chemical exposure guidelines for deployed military personnel. (Technical guide 230, 2013 revision). Aberdeen Proving Ground, MD. https://phc.amedd.army.mil/PHC%20Resource%20Library/TG230-DeploymentEHRA-and-MEGs-2013-Revision.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1986). Health and environmental effects profile for isobutanol [EPA Report]. (EPA/600/X-86/149). Cincinnati, OH. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB89123376
U.S. EPA (U.S. Environmental Protection Agency). (1987). Isobutyl alcohol; CASRN 78-83-1. In Integrated Risk Information System (IRIS). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0169_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (2002a). Integrated Risk Information System (IRIS) chemical assessment summary for isobutyl alcohol. Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0169_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002b). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011). Health effects assessment summary tables for superfund (HEAST): Isobutyl alcohol (CASRN 78-83-1). Available online at https://epa-heast.ornl.gov/heast.php (accessed June 6, 2019).
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories tables [EPA Report]. (EPA 822-F-18-001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100U7U8.txt
U.S. EPA (U.S. Environmental Protection Agency). (2021). TSCA chemical substance inventory. Download the non-confidential TSCA inventory. Available online at https://www.epa.gov/tsca-inventory/how-access-tsca-inventory
Wilkin JK; Fortner G. (1985). Cutaneous vascular sensitivity to lower aliphatic alcohols and aldehydes in Orientals. Alcohol Clin Exp Res 9: 522–525. 10.1111/j.1530-0277.1985.tb05596.x 2936266
Wilkin JK; Stewart JH. (1987). Substrate specificity of human cutaneous alcohol dehydrogenase and erythema provoked by lower aliphatic alcohols. J Invest Dermatol 88: 452–454.3559273
Zeiger E; Anderson B; Haworth S; Lawlor T; Mortelmans K. (1988). Salmonella mutagenicity tests: IV: Results from the testing of 300 chemicals. Environ Mol Mutagen 11: 1–18. 10.1002/em.2850110602