# APPENDIX C DATA EVALUATION METHODS AND RESULTS

## METHODOLOGY

Based on the literature screen, there were 11 separate studies considered relevant to inhalation provisional toxicity values and oral and inhalation cancer weight of evidence (WOE) for isobutyl alcohol. Study evaluation proceeded for eight studies, including a cross-sectional occupational exposure study (Hollett and Aw, 1982), a human patch-test study (Wilkin and Stewart, 1987; Wilkin and Fortner, 1985), two subchronic inhalation studies in rats (Li et al., 1999; Branch et al., 1996; Kaempfe and Li, 1996), a two-generation inhalation study in rats (Nemec, 2003), a developmental inhalation study in rats and rabbits (Klimisch and Hellwig, 1995), and an oral cancer study in rats (Dow Chemical, 1992).

Study evaluations were conducted by two independent reviewers using the U.S. Environmental Protection Agency (U.S. EPA) version of the Health Assessment Workspace Collaborative (HAWC) database, a free and open-source, web-based software application designed to manage and facilitate the process of conducting literature assessments.^8^ Study evaluation conflicts were resolved by discussion between the primary reviewers in consultation with a third reviewer to resolve any remaining disagreements.

The general approach for evaluating human health and animal toxicology studies is presented in Figure C-1. For each of the outcomes in a study, reviewers evaluated each of the domains shown in Figure C-1. Reviewers reached a consensus judgment of good, adequate, deficient, not reported, or critically deficient in each domain, as defined in Figure C-1. Questions used to guide the development of criteria for each domain in human health and animal toxicology studies are presented in Tables C-1 and C-2, respectively. Evaluations were focused on the methodological approaches and adequacy of reporting in the individual studies and did not consider either the direction or the magnitude of the study results. Key concerns for the review of epidemiology and animal toxicology studies are potential sources of bias (factors that could systematically affect the magnitude or direction of an effect) and insensitivity (factors that limit the ability of a study to detect a true effect). Once the evaluation domains were rated, a study confidence rating of high, medium, low, or uninformative for a specific health outcome was determined by considering the strengths and limitations, as defined in Figure C-1. Study confidence ratings were based on reviewer judgments across the evaluation domains, including the likely impact that the noted deficiencies in bias and sensitivity, or inadequate reporting, may have on the results.

Figure C-1 Approach for Evaluating Epidemiological and Animal Toxicology Studies

Figure shows the Approach for Evaluating Epidemiological and Animal Toxicology Studies. A study confidence ratigh of high, medium, low or uninformative for a specific health otucomes was determined by considering the strenghts and limititations defined in Figure C-1.

Table C-1 Questions Used to Guide the Development of Criteria for Each Domain in Epidemiology Studies

Core Question | Prompting Questions | Follow-Up Questions
[underlined: Exposure Measurement]; Does the exposure measure reliably distinguish between levels of exposure in a time window considered most relevant for a causal effect with respect to the development of the outcome? | - For all:; ○ Does the exposure measure capture the variability in exposure among the participants, considering intensity, frequency, and duration of exposure?; ○ Does the exposure measure reflect a relevant time window? If not, can the relationship between measures in this time and the relevant time window be estimated reliably?; ○ Was the exposure measurement likely to be affected by a knowledge of the outcome?; ○ Was the exposure measurement likely to be affected by the presence of the outcome (i.e., reverse causality)?; - For case-control studies of occupational exposures:; ○ Is exposure based on a comprehensive job history describing tasks, setting, time period, and use of specific materials?; - For biomarkers of exposure, general population:; ○ Is a standard assay used? What are the intra- and interassay coefficients of variation? Is the assay likely to be affected by contamination? Are values less than the limit of detection dealt with adequately?; - What exposure time period is reflected by the biomarker? If the half-life is short, what is the correlation between serial measurements of exposure? | - Is the degree of exposure misclassification likely to vary by exposure level?; - If the correlation between exposure measurements is moderate, is there an adequate statistical approach to ameliorate variability in measurements?; - If there is a concern about the potential for bias, what is the predicted direction or distortion of the bias on the effect estimate (if there is enough information)?
[underlined: Outcome Ascertainment]; Does the outcome measure reliably distinguish the presence or absence (or degree of severity) of the outcome? | - For all:; ○ Is outcome ascertainment likely to be affected by knowledge of, or presence of, exposure (e.g., consider access to health care, if based on self-reported history of diagnosis)?; - For case-control studies:; ○ Is the comparison group without the outcome (e.g., controls in a case-control study) based on objective criteria with little or no likelihood of inclusion of people with the disease?; - For mortality measures:; ○ How well does cause of death data reflect occurrence of the disease in an individual? How well do mortality data reflect incidence of the disease?; - For diagnosis of disease measures:; ○ Is diagnosis based on standard clinical criteria? If based on self-report of diagnosis, what is the validity of this measure?; - For laboratory-based measures (e.g., hormone levels):; ○ Is a standard assay used? Does the assay have an acceptable level of interassay variability? Is the sensitivity of the assay appropriate for the outcome measure in this study population? | - Is there a concern that any outcome misclassification is nondifferential, differential, or both?; - What is the predicted direction or distortion of the bias on the effect estimate (if there is enough information)?
[underlined: Participant Selection]; Is there evidence that selection into or out of the study (or analysis sample) was jointly related to exposure and to outcome? | - For longitudinal cohort:; ○ Did participants volunteer for the cohort based on knowledge of exposure and/or preclinical disease symptoms? Was entry into the cohort or continuation in the cohort related to exposure and outcome?; - For occupational cohort:; ○ Did entry into the cohort begin with the start of the exposure?; ○ Was follow-up or outcome assessment incomplete, and if so, was follow-up related to both exposure and outcome status?; ○ Could exposure produce symptoms that would result in a change in work assignment/work status (“healthy worker survivor effect”)?; - For case-control study:; ○ Were controls representative of population and time periods from which cases were drawn?; ○ Are hospital controls selected from a group whose reason for admission is independent of exposure?; ○ Could recruitment strategies, eligibility criteria, or participation rates result in differential participation relating to both disease and exposure?; - For population-based survey:; ○ Was recruitment based on advertisement to people with knowledge of exposure, outcome, and hypothesis? | - Were differences in participant enrollment and follow-up evaluated to assess bias?; - If there is a concern about the potential for bias, what is the predicted direction or distortion of the bias on the effect estimate (if there is enough information)?; - Were appropriate analyses performed to address changing exposures over time in relation to symptoms?; - Is there a comparison of participants and nonparticipants to address whether differential selection is likely?
[underlined: Confounding]; Is confounding of the effect of the exposure likely? | - Is confounding adequately addressed by considerations in…; ○ participant selection (matching or restriction)?; ○ accurate information on potential confounders, and statistical adjustment procedures?; ○ lack of association between confounder and outcome, or confounder and exposure in the study?; ○ information from other sources?; - Is the assessment of confounders based on a thoughtful review of published literature, potential relationships (e.g., as can be gained through directed acyclic graphing), minimizing potential overcontrol (e.g., inclusion of a variable on the pathway between exposure and outcome)? | - If there is a concern about the potential for bias, what is the predicted direction or distortion of the bias on the effect estimate (if there is enough information)?
[underlined: Analysis]; Does the analysis strategy and presentation convey the necessary familiarity with the data and assumptions? | - Are missing outcome, exposure, and covariate data recognized, and if necessary, accounted for in the analysis?; - Does the analysis appropriately consider variable distributions and modeling assumptions?; - Does the analysis appropriately consider subgroups of interest (e.g., based on variability in exposure level or duration, or susceptibility)?; - Is an appropriate analysis used for the study design?; - Is effect modification considered, based on considerations developed a priori?; - Does the study include additional analyses addressing potential biases or limitations (i.e., sensitivity analyses)? | - If there is a concern about the potential for bias, what is the predicted direction or distortion of the bias on the effect estimate (if there is enough information)?
[underlined: Sensitivity]; Is there a concern that sensitivity of the study is not adequate to detect an effect? | - Is the exposure range adequate?; - Was the appropriate population included?; - Was the length of follow-up adequate? Is the time/age of outcome ascertainment optimal given the interval of exposure and the health outcome?; - Are there other aspects related to risk of bias or otherwise that raise concerns about sensitivity?
[underlined: Selective Reporting]; Is there reason to be concerned about selective reporting? | - Are the results needed for the IRIS analysis (based on a priori specification) presented? If not, can these results be obtained?; - Are only statistically significant results presented?

IRIS = Integrated Risk Information System.

Table C-2 Questions Used to Guide the Development of Criteria for Each Domain in Experimental Animal Toxicology Studies

Evaluation Type | Domain–Core Question | Prompting Questions | Basic Considerations
Reporting Quality | Reporting Quality—; Does the study report information for evaluating the design and conduct of the study for the endpoint(s)/outcome(s) of interest?; Notes: Reviewers should reach out to study authors to obtain missing information when studies are considered key for hazard evaluation and/or dose-response. This domain is limited to reporting. Other aspects of the exposure methods, experimental design, and endpoint evaluation methods are evaluated using the domains related to risk of bias and study sensitivity. | Does the study report the following?; - Critical information necessary to perform study evaluation:; ○ Species, test article name, levels and duration of exposure; route (e.g., oral; inhalation), qualitative or quantitative results for at least one endpoint of interest.; - Important information for evaluating the study methods:; ○ Test animal: strain, sex, source, and general husbandry procedures.; ○ Exposure methods: source, purity, method of administration.; ○ Experimental design: frequency of exposure, animal age and life stage during exposure and at endpoint/outcome evaluation.; ○ Endpoint evaluation methods: assays or procedures used to measure the endpoint(s)/outcome(s) of interest. | These considerations typically do not need to be refined by assessment teams, although in some instances the important information may be refined depending on the endpoint(s)/outcome(s) of interest or the chemical under investigation.; A judgment and rationale for this domain should be given for the study. Typically, these will not change regardless of the endpoint(s)/outcome(s) investigated by the study. In the rationale, reviewers should indicate whether the study adhered to GLP, OECD, or other testing guidelines.; - Good: All critical and important information is reported or inferable for the endpoint(s)/outcome(s) of interest.; - Adequate: All critical information is reported, but some important information is missing. However, the missing information is not expected to significantly impact the study evaluation.; - Deficient: All critical information is reported but important information is missing that is expected to significantly reduce the ability to evaluate the study.; - Critically deficient: Study report is missing any pieces of critical information. Studies that are critically deficient for reporting are uninformative for the overall rating and not considered further for evidence synthesis and integration.
Risk of Bias: Selection and Performance Bias | Allocation—; Were animals assigned to experimental groups using a method that minimizes selection bias? | For each study:; - Did each animal or litter have an equal chance of being assigned to any experimental group (i.e., random allocation)?; - Is the allocation method described?; - Aside from randomization, were any steps taken to balance variables across experimental groups during allocation? | These considerations typically do not need to be refined by assessment teams.; [underlined: A judgment and rationale for this domain should be given for each cohort or experiment in the study.]; - Good: Experimental groups were randomized, and any specific randomization procedure was described or inferable (e.g., computer-generated scheme). (Note that normalization is not the same as randomization [see response for adequate].); - Adequate: Study authors reported that groups were randomized but did not describe the specific procedure used (e.g., “animals were randomized”). Alternatively, study authors used a nonrandom method to control for important modifying factors across experimental groups (e.g., body-weight normalization).; - Not reported (interpreted as deficient): No indication of randomization of groups or other methods (e.g., normalization) to control for important modifying factors across experimental groups.; - Critically deficient: Bias in the animal allocations was reported or inferable.
Risk of Bias: Selection and Performance Bias | Observational Bias/Blinding—; Did the study implement measures to reduce observational bias? | For each endpoint/outcome or grouping of endpoints/outcomes in a study:; - Does the study report blinding or other methods/procedures for reducing observational bias?; - If not, did the study use a design or approach for which such procedures can be inferred?; - What is the expected impact of failure to implement (or report implementation) of these methods/procedures on the results? | These considerations typically do not need to be refined by the assessment teams. (Note that it can be useful for teams to identify highly subjective measures of endpoint[s]/outcome[s] where observational bias may strongly influence results prior to performing evaluations.); [underlined: A judgment and rationale for this domain should be given for each endpoint/outcome or group of endpoints/outcomes investigated in the study.]; - Good: Measures to reduce observational bias were described (e.g., blinding to conceal treatment groups during endpoint evaluation; consensus-based evaluations of histopathology lesions).^a^; - Adequate: Methods for reducing observational bias (e.g., blinding) can be inferred or were reported but described incompletely.; - Not reported: Measures to reduce observational bias were not described.; ○ Interpreted as adequate―The potential concern for bias was mitigated based on use of automated/computer-driven systems, standard laboratory kits, relatively simple, objective measures (e.g., body or tissue weight), or screening-level evaluations of histopathology.; ○ Interpreted as deficient―The potential impact on the results is major (e.g., outcome measures are highly subjective).; - Critically deficient: Strong evidence for observational bias that could have impacted results.
Risk of Bias: Confounding/Variable Control | Confounding—; Are variables with the potential to confound or modify results controlled for and consistent across all experimental groups? | For each study:; - Are there differences across the treatment groups (e.g., co-exposures, vehicle, diet, palatability, husbandry, health status, and so forth) that could bias the results?; - If differences are identified, to what extent are they expected to impact the results? | These considerations may need to be refined by assessment teams, as the specific variables of concern can vary by experiment or chemical.; [underlined: A judgment and rationale for this domain should be given for each cohort or experiment in the study, noting when the potential for confounding is restricted to specific endpoint(s)/outcome(s).]; - Good: Outside of the exposure of interest, variables that are likely to confound or modify results appear to be controlled for and consistent across experimental groups.; - Adequate: Some concern that variables that were likely to confound or modify results were uncontrolled or inconsistent across groups but are expected to have a minimal impact on the results.; - Deficient: Notable concern that potentially confounding variables were uncontrolled or inconsistent across groups and are expected to substantially impact the results.; - Critically deficient: Confounding variables were presumed to be uncontrolled or inconsistent across groups and are expected to be a primary driver of the results.
Risk of Bias: Reporting and Attrition Bias | Selective Reporting and Attrition—; Did the study report results for all prespecified outcomes and tested animals?; Note: This domain does not consider the appropriateness of the analysis/results presentation. This aspect of study quality is evaluated in another domain. | For each study:; - Selective reporting bias:; ○ Are all results presented for endpoint(s)/outcome(s) described in the methods (see note)?; - Attrition bias:; ○ Are all animals accounted for in the results?; ○ If there are discrepancies, do study authors provide an explanation (e.g., death or unscheduled sacrifice during the study)?; ○ If unexplained results, omissions, and/or attrition are identified, what is the expected impact on the interpretation of the results? | These considerations typically do not need to be refined by assessment teams.; [underlined: A judgment and rationale for this domain should be given for each cohort or experiment in the study.]; - Good: Quantitative or qualitative results were reported for all prespecified outcomes (explicitly stated or inferred), exposure groups, and evaluation time points. Data not reported in the primary article is available from supplemental material. If results, omissions, or animal attrition is identified, the study authors provide an explanation, and these are not expected to impact the interpretation of the results.; - Adequate: Quantitative or qualitative results are reported for most prespecified outcomes (explicitly stated or inferred), exposure groups and evaluation time points. Omissions and/or attrition are not explained but are not expected to significantly impact the interpretation of the results.; - Deficient: Quantitative or qualitative results are missing for many prespecified outcomes (explicitly stated or inferred), exposure groups and evaluation time points and/or high animal attrition; omissions and/or attrition are not explained and may significantly impact the interpretation of the results.; - Critically deficient: Extensive results omission and/or animal attrition is identified and prevents comparisons of results across treatment groups.
Sensitivity: Exposure Methods Sensitivity | Characterization—; Did the study adequately characterize exposure to the chemical of interest and the exposure administration methods?; Note: Consideration of the appropriateness of the route of exposure is not evaluated at the individual study level. Relevance and utility of the routes of exposure are considered in the PECO criteria for study inclusion and during evidence synthesis. | For each study:; - Does the study report the source and purity and/or composition (e.g., identity and percent distribution of different isomers) of the chemical? If not, can the purity and/or composition be obtained from the supplier (e.g., as reported on the website)?; - Was independent analytical verification of the test article purity and composition performed?; - Did the study authors take steps to ensure the reported exposure levels were accurate?; ○ For inhalation studies: Were target concentrations confirmed using reliable analytical measurements in chamber air?; ○ For oral studies: If necessary, based on consideration of chemical-specific knowledge (e.g., instability in solution; volatility) and/or exposure design (e.g., the frequency and duration of exposure), were chemical concentrations in the dosing solutions or diet analytically confirmed?; - Are there concerns about the methods used to administer the chemical (e.g., inhalation chamber type, gavage volume, etc.)? | It is essential that these criteria are considered and potentially refined by assessment teams, as the specific variables of concern can vary by chemical.; [underlined: A judgment and rationale for this domain should be given for each cohort or experiment in the study.]; - Good: Chemical administration and characterization is complete (i.e., source, purity, and analytical verification of the test article are provided). There are no concerns about the composition, stability, or purity of the administered chemical or the specific methods of administration. For inhalation studies, chemical concentrations in the exposure chambers are verified using reliable analytical methods.; - Adequate: Some uncertainties in the chemical administration and characterization are identified, but these are expected to have minimal impact on interpretation of the results (e.g., source and vendor-reported purity are presented, but not independently verified; purity of the test article is suboptimal but not concerning). For inhalation studies, actual exposure concentrations are missing or verified with less reliable methods.; - Deficient: Uncertainties in the exposure characterization are identified and expected to substantially impact the results (e.g., source of the test article is not reported; levels of impurities are substantial or concerning; deficient administration methods such as use of static inhalation chambers or a gavage volume considered too large for the species and/or life stage at exposure).; - Critically deficient: Uncertainties in the exposure characterization are identified, and there is reasonable certainty that the results are largely attributable to factors other than exposure to the chemical of interest (e.g., identified impurities are expected to be a primary driver of the results).
Sensitivity: Outcome Measures and Results Display | Endpoint Sensitivity and Specificity—; Are the procedures sensitive and specific for evaluating the endpoint(s)/outcome(s) of interest?; Note: Sample size alone is not a reason to conclude an individual study is critically deficient. | For each endpoint/outcome or grouping of endpoints/outcomes in a study:; - Are there concerns regarding the specificity and validity of the protocols?; - Are there serious concerns regarding the sample size (see note)?; - Are there concerns regarding the timing of the endpoint assessment? | Considerations for this domain are highly variable depending on the endpoint(s)/outcome(s) of interest and must be refined by assessment teams.; [underlined: A judgment and rationale for this domain should be given for each endpoint/outcome or group of endpoints/outcomes investigated in the study.]; Examples of potential concerns include:; - Selection of protocols that are insensitive or nonspecific for the endpoint of interest.; - Use of unreliable methods to assess the outcome.; - Assessment of endpoints at inappropriate or insensitive ages, or without addressing known endpoint variation (e.g., due to circadian rhythms, estrous cyclicity, etc.).; - Decreased specificity or sensitivity of the response due to the timing of endpoint evaluation, as compared to exposure (e.g., short-acting depressant or irritant effects of chemicals; insensitivity due to prolonged period of nonexposure prior to testing).
Sensitivity: Outcome Measures and Results Display | Results Presentation—; Are the results presented in a way that makes the data usable and transparent? | For each endpoint/outcome or grouping of endpoints/outcomes in a study:; - Does the level of detail allow for an informed interpretation of the results?; - Are the data analyzed, compared, or presented in a way that is inappropriate or misleading? | Considerations for this domain are highly variable depending on the outcomes of interest and must be refined by assessment teams.; [underlined: A judgment and rationale for this domain should be given for each endpoint/outcome or group of endpoints/outcomes investigated in the study.]; Examples of potential concerns include:; - Nonpreferred presentation such as developmental toxicity data averaged across pups in a treatment group when litter responses are more appropriate.; - Failing to present quantitative results.; - Pooling data when responses are known or expected to differ substantially (e.g., across sexes or ages).; - Failing to report on or address overt toxicity when exposure levels are known or expected to be highly toxic.; - Lack of full presentation of the data (e.g., presentation of mean without variance data; concurrent control data are not presented).
Overall Confidence | Overall Confidence—; Considering the identified strengths and limitations, what is the overall confidence rating for the endpoint(s)/outcome(s) of interest?; Note: Reviewers should mark studies that are rated lower than high confidence only due to low sensitivity (i.e., bias towards the null) for additional consideration during evidence synthesis. If the study is otherwise well conducted and an effect is observed, the confidence may be increased. | For each endpoint/outcome or grouping of endpoints/outcomes in a study:; - Were concerns (i.e., limitations or uncertainties) related to the reporting quality, risk of bias, or sensitivity identified?; - If yes, what is their expected impact on the overall interpretation of the reliability and validity of the study results, including (when possible) interpretations of impacts on the magnitude or direction of the reported effects? | The overall confidence rating considers the likely impact of the noted concerns (i.e., limitations or uncertainties) in reporting, bias, and sensitivity on the results.; [underlined: A confidence rating and rationale should be given for each endpoint/outcome or group of endpoints/outcomes investigated in the study.]; - High: No notable concerns are identified (e.g., most or all domains rated good).; - Medium: Some concerns are identified but expected to have minimal impact on the interpretation of the results (e.g., most domains rated adequate or good; may include studies with deficient ratings if concerns are not expected to strongly impact the magnitude or direction of the results). Any important concerns should be carried forward to evidence synthesis.; - Low: Identified concerns are expected to have significant impact on the study results or their interpretation (e.g., generally, deficient ratings for one or more domains). The concerns leading to this confidence judgment must be carried forward to evidence synthesis (see note).; - Uninformative: Serious flaw(s) that make the study results unusable for informing hazard identification (e.g., generally, critically deficient rating in any domain; many deficient ratings). Uninformative studies are considered no further in the synthesis and integration of evidence.

a For nontargeted or screening-level histopathology outcomes often used in guideline studies, blinding during the initial evaluation of tissues is generally not recommended as masked evaluation can make “the task of separating treatment-related changes from normal variation more difficult” and “there is concern that masked review during the initial evaluation may result in missing subtle lesions.” Generally, blinded evaluations are recommended for targeted secondary review of specific tissues or in instances when there is a predefined set of outcomes that is known or predicted to occur (Crissman et al., 2004).

GLP = Good Laboratory Practice; OECD = Organisation for Economic Co-operation and Development; PECO = Population, Exposure, Comparator, Outcome.

## RESULTS

Based on the study evaluations, all human studies and the animal oral cancer study (Dow Chemical, 1992) were considered low confidence or uninformative (see Figure C-2); therefore, these studies were only briefly discussed in Section 2.3 of this document (see Table 4B).

Figure C-2 Evaluation Results for Human (A) and Animal (B) Studies Assessing Effects of Isobutyl Alcohol

Click to see human interactive (https://hawc.epa.gov/summary/visual/assessment/100500033/study-evaluation-results-human-studies-isobutyl-al/) data graphic and animal interactive data graphic (https://hawc.epa.gov/summary/visual/assessment/100500033/study-evaluation-results-animal-studies-isobutyl-a/) for rating rationales.

Figure C-2 data graphics, side-by-side. Evaluation Results for Human (A) and Animal (B) Studies Assessing Effects of Isobutyl Alcohol.

The remaining five in vivo animal studies are represented in three publications, including one rat and one rabbit developmental study (Klimisch and Hellwig, 1995), two subchronic inhalation studies in rats [Branch et al. (1996); Li and Kaempfe (1996); both studies also presented in Li et al. (1999)], and one two-generation study in rats (Nemec, 2003), which were included in Section 2 of this document (see Table 4A). As shown in Figure C-2, these studies were rated as high or medium confidence.

## DATA EXTRACTION

Information on study design, methods, results, and data from animal toxicology studies were extracted into HAWC and are available at https://hawcprd.epa.gov/assessment/100500033/.

Visual graphics prepared from HAWC are embedded as hyperlinks and are fully interactive when viewed online by way of a “click to see more” capability. Clicking on content allows access to study evaluation ratings, methodological details, and underlying study data. The action of clicking on content contained in those visual graphics (e.g., data points, endpoint, and study design) will yield the underlying data supporting the visual content. Note: The following browsers are fully supported for accessing HAWC: Google Chrome (preferred), Mozilla Firefox, and Apple Safari. There are errors in functionality when viewed with Internet Explorer. Any discrepancies in data extraction were resolved by discussion or consultation with a third member of the evaluation team. Analytical concentrations were extracted as reported in the study and converted to mg/m^3^ human equivalent concentrations (HECs).

8 HAWC: A modular web-based interface to facilitate development of human health assessments of chemicals (https://hawcprd.epa.gov).