# APPENDIX B SYSTEMATIC LITERATURE SEARCH METHODS AND RESULTS

As discussed in the main body of the Provisional Peer-Reviewed Toxicity Value (PPRTV) assessment, a systematic review was conducted to identify studies relevant to the derivation of inhalation provisional toxicity values and oral and inhalation cancer weight of evidence (WOE) for isobutyl alcohol. Because an oral reference dose (RfD) value is available on the U.S. Environmental Protection Agency (U.S. EPA) Integrated Risk Information System (IRIS) database (U.S. EPA, 1987), oral noncancer data for isobutyl alcohol were not reviewed.

## LITERATURE SEARCH

Literature searches were conducted in April 2019 and updated in August 2022 for studies relevant to the derivation of provisional toxicity values for isobutyl alcohol. Searches were conducted using the U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^6^ (including TSCATS1), and Web of Science (see Table B-1). The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), the U.S. EPA Chemical Data Access Tool (CDAT), the U.S. EPA ChemView, the U.S. EPA Integrated Risk Information System (IRIS), the U.S. EPA Health Effects Assessment Summary Tables (HEAST), the U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), the U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO) (see Table B-2).

Table B-1 Database Query Strings for Isobutyl Alcohol (CASRN 78-83-1) (PubMed, TOXLINE, WOS, TSCATS)

Database (search date) | Query String
PubMed 8/1/2022 | (78-83-1[rn] OR “isobutyl alcohol”[nm]) OR ((“1-Hydroxymethylpropane”[tw] OR “1-Propanol, 2-methyl-”[tw] OR “2-METHYL PROPANOL”[tw] OR “2-Methyl-1-propanol”[tw] OR “2-Methylpropan-1-ol”[tw] OR “2-methylpropane-1-ol”[tw] OR “2-Methylpropanol”[tw] OR “2-Methylpropyl alcohol”[tw] OR “Butanol (iso)”[tw] OR “BUTYL ISO ALCOHOL”[tw] OR “Fermentation butyl alcohol”[tw] OR “iso-butanol”[tw] OR “iso-Butyl alcohol”[tw] OR “Isobutanol”[tw] OR “Isobutyl alcohol”[tw] OR “Isopropyl carbinol”[tw] OR “Isopropylcarbinol”[tw]) NOT medline[sb])
WOS 8/1/2022 | TS=(“1-Propanol, 2-methyl-” OR “2-METHYL PROPANOL” OR “2-Methyl-1-propanol” OR “2-Methylpropan-1-ol” OR “2-Methylpropanol” OR “iso-butanol” OR “iso-Butyl alcohol” OR “Isobutanol” OR “Isobutyl alcohol” OR “1-Hydroxymethylpropane” OR “2-methylpropane-1-ol” OR “2-Methylpropyl alcohol” OR “Butanol (iso)” OR “BUTYL ISO ALCOHOL” OR “Fermentation butyl alcohol” OR “Isopropyl carbinol” OR “Isopropylcarbinol”) AND ((WC=(“Toxicology” OR “Endocrinology & Metabolism” OR “Gastroenterology & Hepatology” OR “Gastroenterology & Hepatology” OR “Hematology” OR “Neurosciences” OR “Obstetrics & Gynecology” OR “Pharmacology & Pharmacy” OR “Physiology” OR “Respiratory System” OR “Urology & Nephrology” OR “Anatomy & Morphology” OR “Andrology” OR “Pathology” OR “Otorhinolaryngology” OR “Ophthalmology” OR “Pediatrics” OR “Oncology” OR “Reproductive Biology” OR “Developmental Biology” OR “Biology” OR “Dermatology” OR “Allergy” OR “Public, Environmental & Occupational Health”) OR SU=(“Anatomy & Morphology” OR “Cardiovascular System & Cardiology” OR “Developmental Biology” OR “Endocrinology & Metabolism” OR “Gastroenterology & Hepatology” OR “Hematology” OR “Immunology” OR “Neurosciences & Neurology” OR “Obstetrics & Gynecology” OR “Oncology” OR “Ophthalmology” OR “Pathology” OR “Pediatrics” OR “Pharmacology & Pharmacy” OR “Physiology” OR “Public, Environmental & Occupational Health” OR “Respiratory System” OR “Toxicology” OR “Urology & Nephrology” OR “Reproductive Biology” OR “Dermatology” OR “Allergy”)) OR (WC=“veterinary sciences” AND (TS=“rat” OR TS=“rats” OR TS=“mouse” OR TS=“murine” OR TS=“mice” OR TS=“guinea” OR TS=“muridae” OR TS=rabbit* OR TS=lagomorph* OR TS=hamster* OR TS=ferret* OR TS=gerbil* OR TS=rodent* OR TS=“dog” OR TS=“dogs” OR TS=beagle* OR TS=“canine” OR TS=“cats” OR TS=“feline” OR TS=“pig” OR TS=“pigs” OR TS=“swine” OR TS=“porcine” OR TS=monkey* OR TS=macaque* OR TS=baboon* OR TS=marmoset*)) OR (TS=toxic* AND (TS=“rat” OR TS=“rats” OR TS=“mouse” OR TS=“murine” OR TS=“mice” OR TS=“guinea” OR TS=“muridae” OR TS=rabbit* OR TS=lagomorph* OR TS=hamster* OR TS=ferret* OR TS=gerbil* OR TS=rodent* OR TS=“dog” OR TS=“dogs” OR TS=beagle* OR TS=“canine” OR TS=“cats” OR TS=“feline” OR TS=“pig” OR TS=“pigs” OR TS=“swine” OR TS=“porcine” OR TS=monkey* OR TS=macaque* OR TS=baboon* OR TS=marmoset* OR TS=“child” OR TS=“children” OR TS=adolescen* OR TS=infant* OR TS=“WORKER” OR TS=“WORKERS” OR TS=“HUMAN” OR TS=patient* OR TS=mother OR TS=fetal OR TS=fetus OR TS=citizens OR TS=milk OR TS=formula OR TS=epidemio* OR TS=population* OR TS=exposure* OR TS=questionnaire OR SO=epidemio*)) OR TI=toxic*) Indexes=SCI-EXPANDED, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, CCR-EXPANDED, IC Timespan=All years
TOXLINE 4/9/2019 | (78-83-1 [rn] OR “1-propanol 2-methyl-” OR “2-methyl propanol” OR “2-methyl-1-propanol” OR “2-methylpropan-1-ol” OR “2-methylpropanol” OR “iso-butanol” OR “iso-butyl alcohol” OR “isobutanol” OR “isobutyl alcohol” ) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HAPAB [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
TOXLINE 4/9/2019 | “1-Hydroxymethylpropane” OR “2-methylpropane-1-ol” OR “2-Methylpropyl alcohol” OR “Butanol (iso)” OR “BUTYL ISO ALCOHOL” OR “Fermentation butyl alcohol” OR “Isopropyl carbinol” OR “Isopropylcarbinol”
TSCATS 1 4/9/2019 | 78-83-1 [rn] AND tscats[org]

TSCATS = Toxic Substances Control Act Test Submission; WOS = Web of Science.

Table B-2 Resources Searched to Augment the Database Search Strings for Isobutyl Alcohol (CASRN 78-83-1)

Additional Strategies | Query and/or Link
ChemView | https://chemview.epa.gov/chemview/?tf=2&ch=78-83-1&su=2-5-6-7&as=3-10-9-8&ac=1-15-16-6378999&ma=4-11-1981377&tds=0&tdl=10&tas1=1&tas2=asc&tas3=undefined&tss=&modal=detail&modalId=99839&modalSrc=2-5-10-4
NTP | - https://ntp.niehs.nih.gov/testing/status/agents/ts-78831.html; - 78-83-1; - “isobutanol” “isobutyl alcohol” “2-methyl propanol” “2-methyl-1-propanol”; - “1-propanol, 2-methyl-” “2-methylpropan-1-ol” “2-methylpropanol” “iso-butanol”; - “iso-butyl alcohol”; - “1-hydroxymethylpropane” “2-methylpropane-1-ol” “2-methylpropyl alcohol” “butanol (iso)”; - “butyl iso alcohol” “fermentation butyl alcohol” “isopropyl carbinol” “isopropylcarbinol”
NTP | https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
ACGIH | ACGIH. 2018. 2018 TLVs and BEIs: Based on documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists
ATSDR | http://www.atsdr.cdc.gov/toxprofiles/index.asp
CalEPA | http://www.oehha.ca.gov/tcdb/index.asp
DWSHA | https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf
ECETOC | http://www.ecetoc.org/publications
ECHA | https://echa.europa.eu/substance-information/-/substanceinfo/100.001.044
ECHA | http://echa.europa.eu/information-on-chemicals/information-from-existing-substances-regulation
HEAST | http://epa-heast.ornl.gov/heast.php
HPVIS | https://iaspub.epa.gov/oppthpv/public_search.html_page
IARC | http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf
InChem—OECD SIDS | http://www.inchem.org/pages/sids.html
IRIS | http://www.epa.gov/iris/
JECDB | http://dra4.nihs.go.jp/mhlw_data/jsp/SearchPageENG.jsp
NIOSH | http://www.cdc.gov/niosh/npg/npgdcas.html
OECD (HPV, SIDS, IUCLID) | http://webnet.oecd.org/hpv/ui/Search.aspx
OSHA | http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992
OSHA | http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
OSHA | https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
WHO | https://www.who.int/publications/ (https://www.who.int/publications/i)

ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; BEI = biological exposure index; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; ECETOC = European Centre for Ecotoxicology and Toxicology of Chemicals; ECHA = European Chemicals Agency; HEAST = Health Effects Assessment Summary Tables; HPV = High Production Volume; HPVIS = High Production Volume Information System; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; IUCLID = International Uniform Chemical Information Database; JECDB = Japan Existing Chemical Data Base; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OECD = Organisation for Economic Cooperation and Development; OSHA = Occupational Safety and Health Administration; SIDS = Screening Information Data Sets; TLV = threshold limit value; WHO = World Health Organization.

## SCREENING PROCESS

Two screeners independently conducted a title and abstract screening of the search results using DistillerSR^7^ to identify study records that met the Population, Exposure, Comparator, and Outcome (PECO) eligibility criteria (see Table B-3).

Table B-3 PECO Criteria for Isobutyl Alcohol (CASRN 78-83-1)

PECO Element | Evidence
Population | Humans, laboratory mammals, and other animal models of established relevance to human health (e.g., Xenopus embryos); mammalian organs, tissues, and cell lines; and bacterial and eukaryote models of genetic toxicity.
Exposure | In vivo (all routes), ex vivo, and in vitro exposure to isobutyl alcohol, including mixtures to which isobutyl alcohol may contribute significantly to exposure or observed effects.
Comparator | Any comparison (across dose, duration, or route) or no comparison (e.g., case reports without controls).
Outcome | Any endpoint suggestive of a toxic effect on any bodily system, or mechanistic change associated with such effects. Any endpoint relating to disposition of the chemical within the body.

PECO = Population, Exposure, Comparator, and Outcome.

Records that were included based on title and abstract screening advanced to full-text review using the same PECO eligibility criteria. Full-text copies of potentially relevant records identified from title and abstract screening were retrieved, stored in the HERO database, and independently assessed by two screeners using DistillerSR to confirm eligibility. If studies were considered PECO-relevant based on full-text review, screeners tagged the studies as one of the following study types: human (all studies); animal (oral route); animal (inhalation chronic/carcinogenicity); animal (inhalation subchronic); animal (inhalation reproductive/developmental); animal (inhalation acute); animal (other routes besides oral or inhalation); absorption, distribution, metabolism, and excretion/physiologically based pharmacokinetic (ADME/PBPK); genotoxicity; mechanistic; or reviews/secondary sources. If “animal (oral route)” was selected, reviewers were asked to indicate whether the study was a chronic/carcinogenicity study (yes/no). Because the focus of the PPRTV assessment was to assess data relevant to derivation of provisional reference concentrations (p-RfCs) and inhalation and oral cancer assessment (but not provisional reference doses [p-RfDs]), only studies tagged as animal (inhalation subchronic), animal (inhalation reproductive/developmental), and animal (oral chronic/carcinogenicity study) moved onto the study evaluation stage. All other PECO-relevant studies were retained as supplemental information.

At both title/abstract and full-text review levels, screening conflicts were resolved by discussion between the primary screeners in consultation with a third reviewer to resolve any remaining disagreements.

## RESULTS

Literature searches yielded 1,298 unique records (see Figure B-1). Of the 1,298 studies identified, 1,099 were excluded during title and abstract screening, while 199 were reviewed at the full-text level. After full-text review, 114 studies were excluded, and 74 studies were tagged as supplemental including acute inhalation studies, studies evaluating routes other than inhalation or oral, mechanistic studies, toxicokinetic studies, genotoxicity studies, and reviews and secondary sources of information. Eleven studies were considered further as relevant to inhalation provisional toxicity values and oral and inhalation cancer assessment for isobutyl alcohol, including three human health studies (described in three publications), three subchronic animal inhalation studies (described in one peer-reviewed and two non-peer-reviewed publications), three reproductive/developmental animal inhalation studies (described in one peer-reviewed publication and one non-peer-reviewed publication), and two oral cancer study in animals (described in one foreign language publication and one English translation report).

Figure B-1 Literature Search and Screening Flow Diagram for Isobutyl Alcohol (CASRN 78-83-1)

Literature Search and Screening Flow Diagram for Isobutyl Alcohol (CASRN 78-83-1)

6 Note that this version of TOXLINE is no longer updated (https://www.nlm.nih.gov/databases/download/toxlinesubset.html); therefore, it was not included in the literature search updates performed after April 2019.

7 DistillerSR is a web-based systematic review software used to screen studies available at https://www.evidencepartners.com/products/distillersr-systematic-review-software.