# APPENDIX A SCREENING PROVISIONAL VALUES

Due to the lack of evidence described in the main provisional peer-reviewed toxicity value (PPRTV) assessment, it is inappropriate to derive provisional reference concentrations (p-RfCs) for isobutyl alcohol. However, some information is available for this chemical, which although insufficient to support derivation of a provisional toxicity value under current guidelines, may be of limited use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with deriving of an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

## DERIVATION OF SCREENING PROVISIONAL REFERENCE CONCENTRATIONS

As discussed in the main body of the report, toxicologically relevant effects identified in inhalation studies are limited to a non-peer-reviewed study. While non-peer-reviewed data are considered inappropriate to derive p-RfCs, these data are adequate to derive screening p-RfCs.

### Derivation of Screening Subchronic Provisional Reference Concentration

Decreased body weight in F_1_ and F_2_ male and female pups in the unpublished two-generation rat study (Nemec, 2003) is the most sensitive target of inhalation toxicity identified for isobutyl alcohol. There were biologically significant (≥5%) decreases in body weights of pups of both sexes at all concentrations in both generations. Similar alterations to pup body weight were not observed in a developmental study in rats by Klimisch and Hellwig (1995), although the exposure regimens and experimental design were significantly different among the two studies (two-generations vs. 10 days). For the purposes of this PPRTV assessment, a ≥5% decrease in pup body weight is considered biologically significant by the U.S. Environmental Protection Agency (U.S. EPA). Due to lack of clear dose-response, these data were not amenable to benchmark dose (BMD) modeling. Therefore, the U.S. EPA selected the LOAEL of 1,458 mg/m^3^ (HEC_ER_ = 364.5 mg/m^3^), based on F_2_ pup exposure, as the point of departure (POD) for derivation of the screening subchronic p-RfC.

The screening subchronic p-RfC of 1 mg/m^3^ for isobutyl alcohol is derived by applying a composite uncertainty factor (UF_C_) of 300 (reflecting an interspecies uncertainty factor [UF_A_] of 3, an intraspecies uncertainty factor [UF_H_] of 10, a database uncertainty factor [UF_D_] of 1, and a LOAEL-to-no-observed-adverse-effect level (NOAEL) uncertainty factor [UF_L_] of 10) to the selected POD of 364.5 mg/m^3^, as follows:

Screening Subchronic p-RfC = POD ( HEC ) ÷ UF_C_ = 364.5 mg / m^3^ ÷ 300 = 1 mg / m^3^

Table A-1 summarizes the uncertainty factors for the screening subchronic p-RfC for isobutyl alcohol.

Table A-1 Uncertainty Factors for the Screening Subchronic p-RfC for Isobutyl Alcohol

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans, using toxicokinetic cross-species dosimetric adjustment for extrarespiratory effects from a Category 3 gas, as specified in the U.S. EPA (1994) guidelines for deriving p-RfCs.
UF_D_ | 1 | A UF_D_ of 1 is applied to account for deficiencies and uncertainties in the database. The database includes a comprehensive two-generation toxicity study in rats, that has not been published or peer-reviewed. Other available studies include a subchronic study in rats and developmental studies in rats and rabbits. The database lacks documentation that portal-of-entry effects were evaluated. Based on the available subchronic information (Li et al. (1999), it appears that developmental toxicity is more sensitive than systemic toxicity at least in a subchronic setting, and it is unlikely that additional subchronic studies would provide a lower POD. Therefore, a UF_D_ of 1 was selected.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility, in the absence of information to assess toxicokinetic and toxicodynamic variability of isobutyl alcohol in humans.
UF_L_ | 10 | A UF_L_ of 10 is applied because the POD is a LOAEL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD is a developmental effect observed in a two-generation study.
UFC | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UFC = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of Screening Chronic Provisional Reference Concentration

The screening chronic p-RfC is derived using the same POD for decreased body weight (LOAEL of 1,458 mg/m^3^ [HEC_ER_ = 364.5 mg/m^3^]), based on F_2_ pup exposure in the unpublished two-generation study by Nemec (2003) that serves as the basis for the screening subchronic p-RfC. Therefore, the lowest LOAEL of 1,458 mg/m^3^ (HEC_ER_ = 364.5 mg/m^3^), based on F_2_ pup exposure, was selected as the POD for derivation of the screening chronic p-RfC.

The screening chronic p-RfC of 4 × 10^−1^ mg/m^3^ for isobutyl alcohol is derived by applying a UF_C_ of 1,000 (reflecting a UF_A_ of 3, a UF_H_ of 10, a UF_D_ of 3, and a UF_L_ of 10) to the selected POD of 364.5 mg/m^3^, as follows:

Screening Chronic p-RfC = POD ( HEC ) ÷ UF_C_ = 364.5 mg / m^3^ ÷ 1,000 = 4 × 10^− 1^ mg / m^3^

Table A-2 summarizes the uncertainty factors for the screening chronic p-RfC for isobutyl alcohol.

Table A-2 Uncertainty Factors for the Screening Chronic p-RfC for Isobutyl Alcohol

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans, using toxicokinetic cross-species dosimetric adjustment for extrarespiratory effects from a Category 3 gas, as specified in the U.S. EPA (1994) guidelines for deriving p-RfCs.
UF_D_ | 3 | A UF_D_ of 3 (10^0.5^) is applied to account for deficiencies and uncertainties in the database. The database includes a comprehensive two-generation toxicity study in rats, that has not, however, been published or peer-reviewed. Other available studies include a subchronic study in rats and developmental studies in rats and rabbits. The database lacks documentation that portal-of-entry effects were evaluated and is considered to be overall limited in scope. No chronic inhalation exposure studies were identified to inform the sensitivity of potential systemic effects compared to the identified reproductive/developmental toxicities characterized in Nemec (2003).
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility, in the absence of information to assess toxicokinetic and toxicodynamic variability of isobutyl alcohol in humans.
UF_L_ | 10 | A UF_L_ of 10 is applied because the POD is a LOAEL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD is based on a developmental effect observed in a two-generation study. While the exposure period was less-than-chronic, the developmental period is recognized as a susceptible life stage when exposure during a time window of development is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991).
UFC | 1,000 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UFC = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.