# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Laura M. Carlson, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## CONTRIBUTORS

- Jeff Dean, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- John Stanek, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## SCIENTIFIC TECHNICAL LEADS

- Jeff Dean, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Jay Zhao, PhD, MPH, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Lucina Lizarraga, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Suryanarayana Vulimiri, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## PRIMARY EXTERNAL REVIEWERS

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.