# 3 DERIVATION OF PROVISIONAL VALUES

The lack of toxicity data precludes direct development of cancer or noncancer provisional reference values for 3,5-dinitroaniline. However, screening provisional reference dose (p-RfD) values and screening provisional reference concentration (p-RfC) values are derived based on available data for structurally similar compounds (see Appendix A).

## 3.1 DERIVATION OF ORAL REFERENCE DOSES

There are no data on the effects of 3,5-dinitroaniline in humans or animals exposed orally. Because of the lack of any available data for 3,5-dinitroaniline, subchronic and chronic p-RfDs cannot be derived directly. Instead, screening p-RfDs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, 4-nitroaniline is selected as the most appropriate analogue for 3,5-dinitroaniline for deriving a screening subchronic and chronic p-RfD.

## 3.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

There are no data on the effects of 3,5-dinitroaniline in humans or animals exposed by inhalation. The absence of relevant inhalation data precludes deriving p-RfCs for 3,5-dinitroaniline directly. Instead, screening p-RfCs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, 4-nitroaniline is selected as the most appropriate analogue for 3,5-dinitroaniline for deriving a screening subchronic and chronic p-RfC.

## 3.3 SUMMARY OF PROVISIONAL REFERENCE VALUES

The noncancer provisional reference values for 3,5-dinitroaniline are summarized in Table 5.

Table 5 Summary of Noncancer Reference Values for 3,5-Dinitroaniline (CASRN 618-87-1)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD^a^ (HED/HEC) | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) | Rat/F | Methemoglobinemia | 7 × 10^−4^ | BMDL_1SD_ | 0.22 (based on analogue POD) | 300 | Monsanto (1981) as cited in U.S. EPA (2009b)
Screening chronic p-RfD (mg/kg-d) | Rat/M | Methemoglobinemia | 4 × 10^−4^ | BMDL_1SD_ | 0.11 (based on analogue POD) | 300 | Nair et al. (1990) as cited in U.S. EPA (2009b)
Screening subchronic p-RfC (mg/m^3^) | Rat/M | Methemoglobinemia | 6 × 10^−3^ | BMCL_1SD_ | 1.7 (based on analogue POD) | 300 | Nair et al. (1986) as cited in U.S. EPA (2009b)
Screening chronic p-RfC (mg/m^3^) | Rat/M | Methemoglobinemia | 2 × 10^−3^ | BMCL_1SD_ | 1.7 (based on analogue POD) | 1,000 | Nair et al. (1986) as cited in U.S. EPA (2009b)

a As stated in the text, 4-nitroaniline is selected as the analogue for the screening subchronic and chronic noncancer oral and inhalation toxicity reference values.

BMCL = benchmark concentration lower confidence limit; BMDL = benchmark dose lower confidence limit, one standard deviation; F = female; HEC = human equivalent concentration; HED = human equivalent dose; M = male; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; SD = standard deviation; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005a), there is “Inadequate Information to Assess the Carcinogenic Potential” of 3,5-dinitroaniline (see Table 6). No relevant studies are available in humans or animals. Within the current U.S. EPA Cancer Guidelines (U.S. EPA, 2005a), there is no standard methodology to support the identification of a weight-of-evidence (WOE) descriptor and derivation of provisional cancer risk estimates for data-poor chemicals using an analogue approach. In the absence of an established framework, a screening evaluation of potential carcinogenicity is provided using the methodology described in Appendix B. This evaluation determined that there is a qualitative level of concern for potential carcinogenicity of 3,5-dinitroaniline (see Appendix C).

Table 6 Cancer WOE Descriptor for 3,5-Dinitroaniline (CASRN 618-87-1)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | There are no human carcinogenicity data identified to support this descriptor.
“Likely to Be Carcinogenic to Humans” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | This descriptor is selected due to the lack of adequate data in humans or animals to evaluate the carcinogenic potential of 3,5-dinitroaniline; however, a screening evaluation described in Appendix B indicates a level of concern for potential carcinogenicity of 3,5-dinitroaniline.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available.

NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

The absence of suitable data precludes developing cancer risk estimates for 3,5-dinitroaniline (see Table 7).

Table 7 Summary of Cancer Risk Estimates for 3,5-Dinitroaniline (CASRN 618-87-1)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.