# 1 INTRODUCTION

3,5-Dinitroaniline, CASRN 618-87-1, belongs to the class of compounds known as nitroaromatics, which are often used as intermediates in the preparation of dyes and pesticides (e.g., herbicides). 3,5-Dinitroaniline is a weak explosive but may be nitrated to yield the powerful explosive 2,3,4,5,6-pentanitroaniline (Talmage et al., 1999). It is not listed on U.S. EPA’s Toxic Substances Control Act’s public inventory (U.S. EPA, 2015), nor is it registered with Europe’s Regulation on Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (ECHA, 2015b).

Nitroanilines are normally formed by ammonolysis of the corresponding chloronitrobenzene (Amini and Lowenkron, 2003). 3,5-Dinitroaniline is also produced from the reduction of 1,3,5-trinitrobenzene with sodium sulfide (Booth, 2012). During the production of 2,4,6-trinitrotoluene (TNT), 3,5-dinitroaniline is formed as a byproduct. Thus, 3,5-dinitroaniline has been found in the environment near munitions production and processing facilities (Talmage et al., 1999).

The empirical formula of 3,5-dinitroaniline is C_6_H_5_N_3_O_4_ (see Figure 1). Table 1 summarizes its physicochemical properties. 3,5-Dinitroaniline is a solid in the form of yellow needles at room temperature (Talmage et al., 1999). Its low estimated vapor pressure and low Henry’s law constant indicate that the solid compound is unlikely to volatilize from either dry or moist surfaces. The moderate estimated water solubility and moderate soil adsorption coefficient of 3,5-dinitroaniline indicate that it will have moderate potential to leach to groundwater or undergo runoff after a rain event.

Figure 1 3,5-Dinitroaniline (CASRN 618-87-1) Structure

This is the beginning of the long description for Figure 1. Figure 1 is titled 3 5 Dinitroaniline, C A S Registry Number 6 1 8 dash 8 7 dash 1, Structure. The chemical has the empirical formula of C 6 H 5 N 3 O 4. This is the end of the long description for Figure 1.

Table 1 Physicochemical Properties of 3,5-Dinitroaniline (CASRN 618-87-1)^a^

Property (unit) | Value
Physical state | Solid
Boiling point (°C) | 398 (experimental average)
Melting point (°C) | 162 (experimental average)
Density (g/mL) | 1.59 (predicted average)
Vapor pressure (mm Hg at 25°C) | 1.39 × 10^−5^ (predicted average)
pH (unitless) | NA^b^
Acid dissociation constant (pKa) (unitless) (for protonated compound) | 0.3^b^
Solubility in water (mol/L) | 7.08 × 10^−3^ (experimental average)
Octanol-water partition coefficient (log K_ow_) | 1.89
Henry’s law constant (atm-m^3^/mol at 25°C) | 4.34 × 10^−8^ (predicted average)
Soil adsorption coefficient (K_oc_) (L/kg) | 253–507^c^
Atmospheric OH rate constant (cm^3^/molecule-sec at 25°C) | 1.12 × 10^−12^ (predicted average)
Atmospheric half-life (d) | 13 (estimated)^b^
Relative vapor density (air = 1) | NV^b^
Molecular weight (g/mol) | 183.123
Flash point (closed cup in °C) | 186^a,^ ^b^

a Unless otherwise noted, data were extracted from the U.S. EPA CompTox Chemicals Dashboard (CASRN 618-87-1; https://comptox.epa.gov/dashboard/dsstoxdb/results?search=618-87-1#properties. Accessed July 15, 2020).

b U.S. EPA (2012).

c Talmage et al. (1999).

NA = not applicable; NV = not available.

No toxicity values for 3,5-dinitroaniline were identified from U.S. EPA or other agencies/organizations, as shown in Table 2.

Table 2 Summary of Available Toxicity Values for 3,5-Dinitroaniline (CASRN 618-87-1)

Source^a^ | Value (applicability) | Reference^b^
Noncancer
IRIS | NV | U.S. EPA (2020a)
HEAST | NV | U.S. EPA (2011b)
DWSHA | NV | U.S. EPA (2018)
ATSDR | NV | ATSDR (2018)
IPCS | NV | IPCS (2020)
CalEPA | NV | CalEPA (2019)
OSHA | NV | OSHA (2020a); OSHA (2020b)
NIOSH | NV | NIOSH (2018)
ACGIH | NV | ACGIH (2020)
Cancer
IRIS | NV | U.S. EPA (2020a)
HEAST | NV | U.S. EPA (2011b)
DWSHA | NV | U.S. EPA (2018)
NTP | NV | NTP (2016)
IARC | NV | IARC (2018)
CalEPA | NV | CalEPA (2019)
ACGIH | NV | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration.

b Reference date is the publication date for the database and not the date the source was accessed.

NV = not available.

Non-date-limited literature searches were conducted in May 2020 and updated in June 2021 for studies relevant to the derivation of provisional toxicity values for 3,5-dinitroaniline. Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. The HERO webpage capturing the search results can be found at https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2009. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following databases were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE (https://www.nlm.nih.gov/databases/download/toxlinesubset.html) is no longer updated; therefore, it was not included in the literature search update from June 2021.