# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Amini, B; Lowenkron, S. (2003). Aniline and its derivatives. In Kirk-Othmer Encyclopedia of Chemical Toxicology. Online: John Wiley & Sons, Inc. 10.1002/0471238961.0114091201130914.a01.pub2
Assmann, N; Emmrich, M; Kampf, G; Kaiser, M. (1997). Genotoxic activity of important nitrobenzenes and nitroanilines in the Ames test and their structure-activity relationship. Mutat Res 395: 139–144. 10.1016/s1383-5718(97)00158-7 9465924
ATSDR (Agency for Toxic Substances and Disease Registry). (1995a). Toxicological profile for 1,3-dinitrobenzene and 1,3,5-trinitrobenzene [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp74.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (1995b). Toxicological profile for 2,4,6-trinitrotoluene [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Services. http://www.atsdr.cdc.gov/toxprofiles/tp81.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2016). Toxicological profile for dinitrotoluenes. (TP109). Atlanta, GA: Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp.asp?id=847&tid=165
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Minimal risk levels (MRLs). June 2018. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR).
Bingham, E; McGowan, WJ. (2012). Aromatic nitro and amino compounds. In E Bingham; B Cohrssen (Eds.), Patty’s toxicology: Volume 2 (6th ed., pp. 517–607). Hoboken, NJ: John Wiley & Sons. 10.1002/0471435139.tox057.pub2
Bolt, HM; Degen, GH; Dorn, SB; Plottner, S; Harth, V. (2006). Genotoxicity and potential carcinogenicity of 2,4,6-TNT (trinitrotoluene): structural and toxicological considerations [Review]. Rev Environ Health 21: 217–228. 10.1515/REVEH.2006.21.4.217 17243348
Booth, G. (2012). Nitro compounds, aromatic. In F Ullman; M Bohnet (Eds.), Ullman’s Encyclopedia of Industrial Chemistry (pp. 301–350). Online: John Wiley & Sons. 10.1002/14356007.a17_411
CalEPA (California Environmental Protection Agency). (2017). Prop 65: §69502.2(a)(1)(A). Chemicals known to cause cancer and/or reproductive toxicity that are listed under Health and Safety Code section 25249.8 of the California Safe Drinking Water and Toxic Enforcement Act of 1986. Available online
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
ChemIDplus. (2018). ChemIDplus - a TOXNET database: National Institutes of Health, U.S. Library of Medicine. Retrieved from https://chem.nlm.nih.gov/chemidplus/
Cossum, PA; Rickert, DE. (1985). Metabolism of dinitrobenzenes by rat isolated hepatocytes. Drug Metab Dispos 13: 664–668.2867868
CPDB (Carcinogenic Potency Database). (2011). The carcinogenic potency project: The carcinogenic potency database [Database]: Department of Energy; National Cancer Institute; Environmental Protection Agency; National Institute of Environmental Health Sciences; National Toxicology Program; University of California, Berkeley. Retrieved from https://www.nlm.nih.gov/databases/download/cpdb.html
ECHA (European Chemicals Agency). (2015a). Registered substances. o-Phenylenediamine. EC number 202-430-6. Toxicological information, toxicokinetics, metabolism and distribution, exp Supporting basic toxicokinetic.004. http://echa.europa.eu/information-on-chemicals/registered-substances/-/disreg/substance/100.002.210
ECHA (European Chemicals Agency). (2015b). Registered substances: Perylene-3,4:9,10-tetracarboxydiimide [Database]. Helsinki, Finland. Retrieved from https://echa.europa.eu/registration-dossier/-/registered-dossier/10330
Houser, RM; Stout, LD; Ribelin, WE. (1983). The subchronic toxicity of p-nitroaniline administered to male and female Sprague-Dawley rats for 90 days [Abstract]. Toxicologist 3: 128.
HSDB (Hazardous Substances Data Bank). (2009). 1,3-Benzenediamine. CASRN: 108-45-2. Bethesda, MD: National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5384
HSDB (Hazardous Substances Data Bank). (2012). 1,3-Dinitrobenzene (CASRN: 99-65-0). Bethesda, MD: National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/4017
IARC (International Agency for Research on Cancer). (1991). Trifluralin. In IARC Monographs on the evaluation of carcinogenic risks to humans Occupational exposures in insecticide application, and some pesticides. Lyon, Fronce. http://monographs.iarc.fr/ENG/Monographs/vol53/mono53-22.pdf
IARC (International Agency for Research on Cancer). (1996). Printing processes and printing inks, carbon black and some nitro compounds [IARC Monograph]. In IARC monographs on the evaluation of carcinogenic risks to humans (pp. 154–156). Lyon, France: World Health Organization (WHO). http://monographs.iarc.fr/ENG/Monographs/vol65/mono65.pdf
IARC (International Agency for Research on Cancer). (2018). IARC monographs on the evaluation of carcinogenic risk to humans. http://monographs.iarc.fr/ENG/Monographs/PDFs/index.php
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Kirkland, D; Aardema, M; Henderson, L; Müller, L. (2005). Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens: I. Sensitivity, specificity and relative predictivity. Mutat Res 584: 1–256. 10.1016/j.mrgentox.2005.02.004 15979392
Monsanto (Monsanto Company). (1981). Ninety-day study of p-nitroaniline administered to male and female Sprague-Dawley rats via gavage. (EPA/OTS Doc #878211038). St. Louis, MO.
Nair, RS; Auletta, CS; Schroeder, RE; Johannsen, FR. (1990). Chronic toxicity, oncogenic potential, and reproductive toxicity of p-nitroaniline in rats. Fundam Appl Toxicol 15: 607–621. 10.1016/0272-0590(90)90045-l 2258023
Nair, RS; Johannsen, FR; Levinskas, GJ; Terrill, JB. (1986). Subchronic inhalation toxicity of p-nitroaniline and p-nitrochlorobenzene in rats. Fundam Appl Toxicol 6: 618–627. 10.1093/toxsci/6.4.618 3710033
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA. http://www.cdc.gov/niosh/npg/npgdcas.html
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
NTP (National Toxicology Program). (2017). NTP technical reports index. Available online at https://ntp.niehs.nih.gov/results/summaries/chronicstudies/index.html
OECD (Organisation for Economic Co-operation and Development). (2018). The OECD QSAR toolbox for grouping chemicals into categories. Retrieved from https://www.qsartoolbox.org/
OSHA (Occupational Safety & Health Administration). (2020a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2020b). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
Sabbioni, G; Jones, CR. (2002). Biomonitoring of arylamines and nitroarenes [Review]. Biomarkers 7: 347–421. 10.1080/13547500210147253 12437855
SOCMA (Synthetic Organic Chemical Manufacturers Association). (2000). Methemoglobin inducing potential of various substituted anilines with cover letter dated 121984 [TSCA Submission]. (EPA/OTS Doc #40-8476328). Washington, DC.
Spanggord, RJ; Mortelmans, KE; Griffin, AF; Simmon, VF. (1982). Mutagenicity in Salmonella typhimurium and structure-activity relationships of wastewater components emanating from the manufacture of trinitrotoluene. Environ Mol Mutagen 4: 163–179. 10.1002/em.2860040207
Talmage, SS; Opresko, DM; Maxwell, CJ; Welsh, CJ; Cretella, FM; Reno, PH; Daniel, FB. (1999). Nitroaromatic munition compounds: environmental effects and screening values [Review]. Rev Environ Contam Toxicol 161: 1–156. 10.1007/978-1-4757-6427-7_1 10218448
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA/600/6-87/008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1997). Support document for 1,3,5-trinitrobenzene (TNB) (CASRN 99-35-4). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/supdocs/tnbsup.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002a). Integrated risk information system (IRIS) chemical assessment summary for 2,4,6-trinitrotoluene (TNT) (CASRN 118-96-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0269_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002b). Integrated risk information system (IRIS) chemical assessment summary for m-phenylenediamine (CASRN 108-45-2). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0087_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Integrated Risk Information System (IRIS) chemical assessment summary for m-dinitrobenzene (CASRN 99-65-0) [Fact Sheet]. Arlington, VA: National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0318_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2006). Provisional peer-reviewed toxicity values for 1,4-dinitrobenzene (p-dinitrobenzene) (CASRN 100-25-4). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Dinitrobenzene14.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009a). Provisional Peer-Reviewed Toxicity Values for 3-nitroaniline (CASRN 99-09-2) [EPA Report]. Cincinnati, OH: National Center for Environmental Assessment. http://hhpprtv.ornl.gov/issue_papers/Nitroaniline3.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009b). Provisional Peer-Reviewed Toxicity Values for 4-Nitroaniline (CASRN 100-01-6) [EPA Report]. Cincinnati, OH: National Center for Environmental Assessment. http://hhpprtv.ornl.gov/issue_papers/Nitroaniline4.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Chemical Assessment Clustering Engine (ChemACE) [Database]. Retrieved from https://www.epa.gov/tsca-screening-tools/chemical-assessment-clustering-engine-chemace
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA/100/R-11/0001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11 [Computer Program]. Washington, DC. Retrieved from https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface
U.S. EPA (U.S. Environmental Protection Agency). (2015). About the TSCA chemical substance inventory. Download the non-confidential TSCA inventory [Database]. Retrieved from http://www2.epa.gov/tsca-inventory/how-access-tsca-inventory
U.S. EPA (U.S. Environmental Protection Agency). (2017). IRIS carcinogens: §69502.2(a)(1)(E). Chemicals that are identified as “carcinogenic to humans,” “likely to be carcinogenic to humans,” or Group A, B1, or B2 carcinogens in the United States Environmental Protection Agency’s Integrated Risk Information System. Available online
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2020b). Provisional peer-reviewed toxicity values (PPRTVs) for superfund: Derivation support documents [Database]. Washington, DC. Retrieved from https://www.epa.gov/pprtv
Wang, NC; Zhao, QJ; Wesselkamper, SC; Lambert, JC; Petersen, D; Hess-Wilson, JK. (2012). Application of computational toxicological approaches in human health risk assessment. I. A tiered surrogate approach. Regul Toxicol Pharmacol 63: 10–19. 10.1016/j.yrtph.2012.02.006 22369873
Xu, JB; Jing, TS; Yang, L; Sun, ZW; Shi, L. (2006). Effects of nitrobenzenes on DNA damage in germ cells of rats. Chem Res Chin Univ 22: 29–32. 10.1016/S1005-9040(06)60039-1
Zulalian, J. (1990). Study of the absorption, excretion, metabolism, and residues in tissues in rats treated with carbon-14-labeled pendimethalin, PROWL herbicide. J Agric Food Chem 38: 1743–1754.