# APPENDIX C RESULTS OF THE SCREENING EVALUATION OF POTENTIAL CARCINOGENICITY

## STEP 1 USE OF AUTOMATED TOOLS TO IDENTIFY STRUCTURAL ANALOGUES WITH GENOTOXICITY AND/OR CARCINOGENICITY DATA

U.S. EPA’s Chemical Assessment Clustering Engine (ChemACE) clustering was performed as described in Appendix B. The cluster containing 3,5-dinitroaniline (less restrictive approach; Cluster 85) contains four structural analogues. All members of the cluster contain a benzene ring fragment substituted with one or more amine groups (−NH_2_) and one or more nitro (−NO_2_) groups; the location and number of the substituents vary. For example, the structure of the target compound shown in Figure C-1 contains one benzene ring, one amine group, and two nitro groups in the 3 and 5 (meta) positions.

Figure C-1 Illustration of Common Fragments in Cluster 85

The Organisation for Economic Co-operation and Development (OECD) quantitative structure-activity relationship (QSAR) Toolbox Profiler was used to identify structural analogues from the Dice analogue search with genotoxicity and/or carcinogenicity data (see Step 1 methods in Appendix B). This process identified an additional 58 compounds to be considered as potential analogues for 3,5-dinitroaniline. Two target compounds (2-amino-4,6-dinitrotoluene and 4-amino-2,6-dinitrotoluene) were also identified by this search; however, these compounds are being evaluated in separate provisional toxicity value documents and were not considered potential analogues for 3,5-dinitroaniline. Refinement of selection of final analogues is described below.

## STEP 2 ANALOGUE REFINEMENT USING EXPERT JUDGMENT

Expert judgment was applied to refine the initial list of 62 potential analogues based on physicochemical properties; absorption, distribution, metabolism, and excretion (ADME); and mechanisms of toxicity.

Compounds were considered potential analogues if they had a benzene or toluene ring substituted with two or three nitro groups, amines, or hydroxylamines. As discussed in Appendix A during selection of noncancer analogues, both meta- and para-substituted compounds were considered as potential analogues based on metabolic and toxicological considerations (the bioreactivity of ortho-substituted compounds is expected to be lower due to steric reasons).

Of the 62 chemicals identified as potential analogues by ChemACE clustering and the OECD Toolbox analogue selection tool (Dice), 54 were not selected for further review. Common rationales for not selecting these chemicals included substitution in the ortho position, ring systems other than benzene or toluene, and occurrence of functional groups absent in 3,5-dinitroaniline (e.g., phenols, halogens, carboxylic acids). Each of these attributes introduce significant differences in bioavailability, reactivity, and applicable metabolic pathways relative to 3,5-dinitroaniline. Dinitrotoluene compounds were also excluded because the primary metabolic pathway for these compounds is methyl group oxidation leading to the formation of a carboxylic acid (ATSDR, 2016), and this pathway is not possible for 3,5-dinitroaniline (see Appendix A for further details). Additionally, methyldinitrobenzene (CASRN 25321-14-6) was not selected for further review because the CASRN/name does not specify the placement of the nitro groups on the ring. It cannot be ruled out that the nitro groups are ortho to one another, or that this substance is a mixture that contains the ortho isomer.

The remaining eight possible analogues for 3,5-dinitroaniline are listed in Table C-1. The existence of a cancer risk estimate and/or a WOE determination for cancer is indicated for each analogue.

Table C-1 Summary of Cancer Assessment Information for Analogues of 3,5-Dinitroaniline (CASRN 618-87-1)^a^

Analogue Name; (CASRN) | Cancer Risk Estimates; (if available) | WOE; Determinations
1,3-Dinitrobenzene^b^; (99-65-0) | None | U.S. EPA (2005b)―not classifiable
1,3,5-Trinitrobenzene^b^; (99-35-4) | None | None
1,4-Dinitrobenzene^b^; (100-25-4) | None | U.S. EPA (2006)―inadequate information
3-Nitroaniline^b,^ ^c^; (99-09-2) | None | U.S. EPA (2009a)―inadequate information
4-Nitroaniline^c^; (100-01-6) | U.S. EPA (2009b)―p-OSF | U.S. EPA (2009b)―suggestive evidence
2,4,6-Trinitrotolulene^b^; (118-96-7) | U.S. EPA (2002a)―OSF | U.S. EPA (2002a)―possible; IARC (1996)―not classifiable; CalEPA (2017)―known
2,4-Dihydroxyamino-6-nitrotoluene^b^; (185376-54-9) | None | None
2-Hydroxylamino-4,6-dintrotoluene^b^; (59283-76-0) | None | None

a Gray shading indicates that there was not a cancer risk estimate and/or a WOE determination for cancer for that analogue.

b Found in Dice.

c Found in ChemACE.

OSF = oral slope factor; p-OSF = provisional oral slope factor; WOE = weight of evidence.

Three compounds that lack a cancer risk estimate or WOE determination (highlighted in gray in Table C-1) were not further considered as a potential analogue for the screening evaluation of potential carcinogenicity of 3,5-dinitroaniline. Compounds selected for further consideration were 1,3-dinitrobenezene, 1,4-dinitrobenzene, 3-nitroaniline, 4-nitroaniline, and 2,4,6-trinitrotoluene (TNT).

## STEP 3 COMPARISON OF THE EXPERIMENTAL GENOTOXICITY DATA FOR 3,5-DINITROANILINE AND ANALOGUES

The very limited genotoxicity data available for 3,5-dinitroaniline are described in the “Other Data” section in the main body of this report (summarized in Table 4). Available data indicate that 3,5-dinitroaniline is mutagenic to bacteria in vitro with and without metabolic activation. A summary of the available genotoxicity data for potential analogues is provided below. In general, data indicate that these compounds are mutagenic in bacterial systems and there is evidence of clastogenicity for some analogues.

1,3-Dinitrobenzene, 3-nitroaniline, 4-nitroaniline, and TNT were mutagenic in bacterial systems in the presence and absence of metabolic activation (U.S. EPA, 2009a, b; Bolt et al., 2006; U.S. EPA, 2006, 2005b; ATSDR, 1995a, b). Mutagenicity was generally increased with metabolic activation, and mutations were not observed in nitroreductase-deficient strains, indicating that metabolites are the primary mutagens. Weak and inconsistent evidence of mutagenicity in bacteria was observed for 1,4-dintrobenzene (U.S. EPA, 2006).

Limited mammalian cell mutagenicity data for TNT produced inconsistent findings (i.e., positive in the mouse lymphoma assay without metabolic activation; negative in V79 Chinese hamster cells, with and without metabolic activation) (Bolt et al., 2006; ATSDR, 1995b). 4-Nitroaniline did not cause forward gene mutations in Chinese hamster ovary cells (U.S. EPA, 2009b). No data on mammalian cell mutagenicity are available for 1,3-dinitrobenzene, 1,4-dinitrobenzene, or 3-nitroaniline. Sex-linked recessive lethal mutations were not observed in Drosophila melanogaster larvae exposed to 4-nitroaniline (U.S. EPA, 2009b); no studies in D. melanogaster were identified for other analogues.

1,3-Dinitrobenene, 1,4-dinitrobenzene, and 4-nitroaniline induced chromosomal aberrations (CAs) in human peripheral lymphocytes exposed in vitro (U.S. EPA, 2009b, 2006). In hamster cells, CAs were induced by 3-nitroaniline and CAs and sister chromatid exchanges were induced by 4-nitroaniline (U.S. EPA, 2009a, b). In in vivo studies, micronuclei (MN) frequency was increased in mice exposed to 3-nitroaniline, but not in mice exposed to 4-nitroaniline or rats exposed to TNT (U.S. EPA, 2009a, b; Bolt et al., 2006; ATSDR, 1995b). TNT also did not induce CAs in in vivo studies in rats (Bolt et al., 2006; ATSDR, 1995b).

1,3-Dinitrobenzene induced deoxyribonucleic acid (DNA) damage in male rat germ cells exposed in vitro (Xu et al., 2006). Unscheduled DNA synthesis (UDS) was not observed in vitro in human fibroblasts exposed to TNT or rat liver cells exposed to 1,3-dinitrobenene, 1,4-dinitrobenzene, 3-nitroaniline, or 4-nitroaniline (U.S. EPA, 2009a, b, 2006, 2002a; ATSDR, 1995a, b). UDS was also not observed in mouse liver cells following in vivo exposure to TNT (ATSDR, 1995b). Covalent ribonucleic acid (RNA) binding was observed in human granulocytes exposed to 4-nitroaniline; however, binding to DNA was at the limit of detection (U.S. EPA, 2009b).

## STEP 4 TOXICOKINETICS OF 3,5-DINITROANILINE AND ANALOGUES

The toxicokinetics of 3,5-dinitroaniline and potential analogues are briefly described in Table C-2. There are no data available regarding the toxicokinetics of 3,5-dinitroaniline or 3-nitroaniline. 1,3-Dinitrobenzene, 1,4-dinitrobenzene, 4-nitroaniline, and TNT are all well absorbed via the oral route, have low potential for accumulation in the body, and are primarily excreted in the urine (U.S. EPA, 2009b, 2006; ATSDR, 1995a, b). Experimental data for 1,3-dintrobenzene, 1,4-dinitrobenzene, and TNT indicate that metabolism occurs via common pathways, including sequential nitroreduction followed by N-acetylation or ring hydroxylation (U.S. EPA, 2006; ATSDR, 1995a, b; Cossum and Rickert, 1985). N-Acetylation may occur in the liver or in the bladder, where the acidic pH subsequently promotes formation of nitrenium ions that form DNA adducts (Sabbioni and Jones, 2002). No data on the primary metabolic pathway for 4-nitroaniline were available; however, analysis of unidentified urinary metabolites indicated that 56% consisted of two sulfate conjugates (U.S. EPA, 2009b).

Table C-2 Summary of Toxicokinetic Data for 3,5-Dinitroaniline and Candidate Analogues

Compound | Absorption, Distribution, Excretion | Metabolism | References
3,5-Dinitroaniline (target) | ND | ND | NA
1,3-Dinitrobenzene | - Well absorbed via oral route; - Low potential for accumulation, ND on deposition; - Primarily excreted in urine | - Primary pathway: sequential nitroreduction followed by N-acetylation or ring hydroxylation, forming hydroxylamine intermediates; - Some of the resulting metabolites are subsequently conjugated with sulfate or glucuronic acid; - Primary urinary metabolites in rats: 3-aminoacetanilide (22%), 4-acetamidophenyl sulfate (6%), 1,3-diacetamidobenzene (7%), and 3-nitroaniline-N-glucuronide | U.S. EPA (2006); ATSDR (1995a); Cossum and Rickert (1985)
1,4-Dintrobenzene | - Well absorbed via oral route; - Low potential for accumulation, ND on deposition; - Primarily excreted in urine | - Primary pathway: sequential nitroreduction followed by N-acetylation or ring hydroxylation; - Some of the resulting metabolites are subsequently conjugated with sulfate; - Primary urinary metabolites in rats: 2-amino-5-nitrophenyl sulfate (35%), S-(4-nitrophenyl)-N-acetylcysteine (13%), and 1,4-diacetamindobenzene (7%); - Secondary pathway: glutathione conjugation | U.S. EPA (2006)
3-Nitroaniline | ND | ND | U.S. EPA (2009b)
4-Nitroaniline | - Well absorbed via oral route; - Low potential for accumulation, no preferential deposition; - Primarily excreted in urine | - ND on primary metabolic pathway; - Nine unidentified metabolites in rat urine; 56% consisted of two sulfate conjugates | U.S. EPA (2009b)
2,4,6-Trinitrotoluene | - Well absorbed via oral route; - Low potential for accumulation, no preferential deposition; - Primarily excreted in urine | - Primary pathway: sequential nitroreduction followed by N-acetylation or ring hydroxylation, forming hydroxylamine intermediates; - Additional pathways: oxidation of methyl group and benzene ring; - Primary metabolites identified in human urine include 2-amino-4,6-dinitrotoluene, 4-amino-2,6-dinitrotoluene, 2,4-diamino-6-nitrotoluene, 4-hydroxylamino-2,6-dintrotoluene, and 3-hydroxy-4-amino-2,6-dinitrotoluene; - Similar metabolites were identified in rat, mouse, rabbit, and dog urine | ATSDR (1995b)

NA = not applicable; ND = no data.

In summary, available data for four analogues identify nitroreduction followed by N-acetylation or ring hydroxylation as the primary metabolic pathway. This pathway is plausible for the target compound as well as analogues lacking metabolism data.

## STEP 5 CARCINOGENICITY OF 3,5-DINITROANILINE ANALOGUES AND MOA DISCUSSION

U.S. EPA cancer WOE descriptors for 3,5-dinitroaniline and its analogue compounds are shown in Table C-3. As noted in the main PPRTV document, there is inadequate information to assess the carcinogenic potential of 3,5-dinitroaniline. Under the 2005 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), there is “Suggestive Evidence of Carcinogenic Potential” for 4-nitroaniline and “Inadequate Information to Assess Carcinogenic Potential” for 1,4-dinitrobenzene and 3-nitroaniline. U.S. EPA carcinogenicity assessments for TNT and 1,3-dinitrobenzene predated these guidelines, and the WOE descriptors were “Possible Human Carcinogen (Group C)” for TNT and “Not Classifiable as to Human Carcinogenicity (Group D)” for 1,3-dinitrobenzene. The Group C designation for TNT was based on increased urinary bladder tumors in female rats (U.S. EPA, 2002a). For 4-nitroaniline, the WOE of “Suggestive Evidence” was based on increased vascular tumors (hemangiomas and hemangiosarcomas, particularly in the liver) in male mice treated orally (U.S. EPA, 2009b). In both cases, data were sufficient to derive oral slope factor (OSF) values (provisional for 4-nitroaniline), and these are similar in magnitude. No cancer data were available for 1,3-dintrobenzene, 1,4-dinitrobenzene, or 3-nitroaniline.

The U.S. EPA (2009b) proposed a mutagenic MOA for 4-nitroaniline; however, support for this MOA is exclusively from in vitro data, and no evidence linking mutagenesis to the development of observed vascular cell tumors was available. The carcinogenic MOA has not been established for TNT, although it exhibits some evidence of genotoxicity (see Step 3).

Table C-3 Comparison of Available Oral Carcinogenicity Data for 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues

Type of Data | 3,5-Dinitroaniline; CASRN 618-87-1 (target) | 1,3-Dinitrobenzene; CASRN 99-65-0 | 1,4-Dintrobenzene; CASRN 100-25-4 | 3-Nitroaniline; CASRN 99-09-2 | 4-Nitroaniline; CASRN 100-01-6 | 2,4,6-Trinitrotoluene; CASRN 118-96-7
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
U.S. EPA WOE characterization | “Inadequate Information to Assess Carcinogenic Potential”; (see Table 6) | “Not Classifiable as to Human Carcinogenicity (Group D)” | “Inadequate Information to Assess Carcinogenic Potential” | “Inadequate Information to Assess Carcinogenic Potential” | “Suggestive Evidence of Carcinogenic Potential” | “Possible Human Carcinogen (Group C)”
OSF (mg/kg-d)^−1^ | NV | NV | NV | NV | 2 × 10^−2^ (provisional) | 3 × 10^−2^
Data set(s) used for slope factor derivation | NV | NV | NV | NV | Hemangiomas or hemangiosarcomas (all sites) in male B6C3F1 mice | Urinary bladder tumors in female F344 rats (transitional cell papilloma and transitional squamous cell carcinomas)
Other tumors observed in animal bioassays | NV | ND | ND | ND | No additional tumors identified | Leukemia and/or malignant lymphoma of the spleen in female B6C3F1 mice
Study doses (mg/kg-d) | NV | NV | NV | NV | 0, 3, 30, 100; ADD: 0, 2.1, 21.4, 71.4; HED: Not reported per dose (HED conversion done after OSF calculation) | 0, 0.4, 2, 10, 50; HED: 0, 0.065, 0.325, 1.623, 8.117
Route (method) | NV | NV | NV | NV | Gavage | Diet
Duration | NV | NV | NV | NV | 2 yr | 24 mo
POD type | NV | NV | NV | NV | BMDL_10_ (HED) | BMDL (linearized multistage procedure, extra risk; no further details reported)
Source | NV | U.S. EPA (2005b) | U.S. EPA (2006) | U.S. EPA (2009a) | U.S. EPA (2009b) | U.S. EPA (2002a)

ADD = adjusted daily dose; BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., subscripted 10 = exposure concentration associated with 10% extra risk); BMR = benchmark response; HED = human equivalent dose; ND = no data; NV = not available; OSF = oral slope factor; POD = point of departure; WOE = weight of evidence.

## STEP 6 STRUCTURAL ALERTS AND STRUCTURE ACTIVITY RELATIONSHIP PREDICTIONS FOR 3,5-DINITROANILINE AND ANALOGUES

Structural alerts (SAs) and predictions for genotoxicity and carcinogenicity were identified using computational tools as described in Appendix B. The model results for 3,5-dinitroaniline and its analogue compounds are shown in Table C-4. Concerns for carcinogenicity and/or mutagenicity of 3,5-dinitroaniline and its analogues were indicated by several models within each predictive tool (see Table C-4). Table C-5 provides a list of the specific SAs that underlie the findings of a concern for carcinogenicity or mutagenicity in Table C-4.

OECD QSAR Toolbox, ToxRead, and Virtual models for property Evaluation of chemicals within a Global Architecture (VEGA) models showed a concern for mutagenicity for 3,5-dinitroaniline and all analogues based on SAs (see Table C-5). The Toxtree tool indicated that 3,5-dinitroaniline, 3-nitroaniline, and 4-nitroaniline were unlikely to be mutagenic in Salmonella TA100 based on QSAR. The Toxtree results for the nitroaniline compounds are inconsistent with positive experimental data (see Step 3), as well as the results of the other QSAR models.

OECD QSAR Toolbox models showed a concern for carcinogenicity for 3,5-dinitroaniline and all analogues based on SAs (see Table C-5). The level of carcinogenicity concern in OncoLogic for 3,5-dinitroaniline was “moderate” based on structure-activity relationship (SAR) predictions only (aromatic compound containing three amino/amine-generating groups, two of which are nitro groups). OncoLogic indicated the level of concern for carcinogenicity as “low-moderate” for 1,3-dinitrobenzene, 3-nitroaniline, and TNT (shown as “no data” in the heat map) and “marginal” for 1,4-dinitrobenzene and 4-nitroaniline (shown as “no data” in the heat map). VEGA showed concern for carcinogenicity of 3,5-dinitroaniline, 1,3-dinitrobenzene, 1,4-dinitrobenzene, and TNT using the Istituto Superiore di Sanità (ISS), Istituto di Ricerche Farmacologiche Mario Negri (IRFMN)/Alternative Non-Testing Methods Assessed for REACH Substances (ANTARES), and IRFMN/Istituto Superiore di Sanità Chemical Carcinogen (ISSCAN-CGX) models, but not the Computer Assisted Evaluation of industrial chemical Substances According to Regulations (CAESAR) model. For 3-nitroaniline, VEGA showed concern for carcinogenicity using the ISS and IRFMN/ISSCAN-CGX models but not the CAESAR model (no data for the IRFMN/ANTARES model). No concern for carcinogenicity was shown for 4-nitroaniline using the CAESAR, IRFMN/ANTARES, and IRFMN/ISSCAN-CGX models (no data for the ISS model). These results are inconsistent with positive carcinogenicity data for 4-nitroaniline (see Step 5). The Toxtree tool indicated that 3,5-dinitroaniline, 3-nitroaniline, and 4-nitroaniline were potential carcinogens based on QSAR. According to this tool, there was no concern for nongenotoxic carcinogenicity for 3,5-dinitroaniline or any of its analogues.

The ToxAlerts tool showed a concern for genotoxic carcinogenicity and/or mutagenicity for 3,5-dinitroaniline and all analogues based on various SAs (see Table C-5). The Toxtree models also suggest a concern for genotoxic carcinogenicity for 3,5-dinitroaniline and all analogues based on SAs (see Table C-5).

Overall, these in silico tools indicate some evidence of mutagenicity and/or carcinogenicity, as well as showing shared metabolic pathways, common SAs (aromatic nitro, nitroarenes, polynitroarenes), and SAR predictions. Although there are some inconsistencies that varied by model system, most predictive SAR tools show concern for mutagenicity/carcinogenicity (summarized in Tables C-4, C-5, and C-6).

Table C-4 Heat Map Illustrating the SA and SAR Prediction Results for 3,5-Dinitroaniline (CASRN 618-87-1) and Analogues

Tool | Model^a^ | 3,5-Dinitroaniline | 1,3-Dinitrobenzene | 1,4-Dinitrobenzene | 3-Nitroaniline | 4--Nitroaniline | 2,4,6-Trinitrotoluene
Mutagenicity/genotoxicity alerts
OECD QSAR Toolbox | DNA alerts for Ames by OASIS
OECD QSAR Toolbox | In vitro mutagenicity (Ames test) alerts by ISS
OECD QSAR Toolbox | In vivo mutagenicity (micronucleus) alerts by ISS
OECD QSAR Toolbox | Protein binding alerts for chromosomal aberration by OASIS
ToxRead | ToxRead (mutagenicity)
VEGA | Mutagenicity (Ames test) CONSENSUS model―assessment
VEGA | Mutagenicity (Ames test) model (CAESAR)―assessment
VEGA | Mutagenicity (Ames test) model (SARpy/IRFMN)―assessment
VEGA | Mutagenicity (Ames test) model (ISS)―assessment
VEGA | Mutagenicity (Ames test) model (k-NN/read-across)―assessment
Toxtree | Potential Salmonella typhimurium TA100 mutagen based on QSAR
Carcinogenicity alerts
OECD QSAR Toolbox | Carcinogenicity (genotoxicity and nongenotoxicity) alerts by ISS
OncoLogic | OncoLogic (prediction of the carcinogenic potential of the chemical)
VEGA | Carcinogenicity model (CAESAR)―assessment
VEGA | Carcinogenicity model (ISS)―assessment
VEGA | Carcinogenicity model (IRFMN/ANTARES)―assessment
VEGA | Carcinogenicity model (IRFMN/ISSCAN-CGX)―assessment
Toxtree | Potential carcinogen based on QSAR
Toxtree | Nongenotoxic carcinogenicity
Combined alerts
ToxAlerts | Aromatic amine (general) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aromatic amine (specific) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aromatic amines (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aromatic nitro (general) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aromatic nitro (specific) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aromatic nitro groups (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Nitroarenes (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Nitro-aromatic (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Primary and secondary aromatic amines (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Primary ar. amine, hydroxyl amine and its derived esters or amine generating group (genotoxicity, carcinogenicity, mutagenicity)
Toxtree | Structural alert for genotoxic carcinogenicity
| Model results or alerts indicating no concern for carcinogenicity/mutagenicity.
| Model results outside the applicability domain for carcinogenicity/mutagenicity.
| Model results or alerts indicating concern for carcinogenicity/mutagenicity.

a All tools and models described in Appendix B were used. Models with results or alerts are presented in the heat map (models without results were omitted).

ANTARES = Alternative Non-Testing Methods Assessed for REACH Substances; CAESAR = Computer-Assisted Evaluation of industrial chemical Substances According to Regulations; CONSENSUS = consensus assessment based on multiple models (CAESAR, SARpy, ISS, and k-NN); DNA = deoxyribonucleic acid; IRFMN = Istituto di Ricerche Farmacologiche Mario Negri; ISS = Istituto Superiore di Sanità; ISSCAN-CGX = Istituto Superiore di Sanità Chemical Carcinogen; k-NN = k-nearest neighbor; OECD = Organisation for Economic Co-operation and Development; SA = structural alert; SAR = structure-activity relationship; QSAR = quantitative structure-activity relationship; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

Table C-5 SAs and Chemical Mechanisms for 3,5-Dinitroaniline (CASRN 618-87-1) and Analogues

SA | Tools | Compounds
Aromatic amine | OncoLogic (includes compounds with amine generating groups) | 3,5-Dinitroaniline, 1,3-dinitrobenzene,^a^ 1,4-dinitrobenzene,^a^ 3-nitroaniline,^a^ 4-nitroaniline^a^
Aromatic amine | ToxAlerts | 3,5-Dinitroaniline, 3-nitroaniline, 4-nitroaniline
Aromatic nitro/nitro-aromatic | ToxAlerts | 3,5-Dinitroaniline, 3-nitroaniline, 1,3-dinitrobenzene, 4-nitroaniline, 2,4,6-trinitrotoluene, 1,4-dinitrobenzene
Aromatic nitro/nitro-aromatic | OECD QSAR Toolbox | 3,5-Dinitroaniline, 3-nitroaniline, 1,3-dinitrobenzene, 4-nitroaniline, 2,4,6-trinitrotoluene, 1,4-dinitrobenzene
Aromatic nitro/nitro-aromatic | Toxtree | 3,5-Dinitroaniline, 3-nitroaniline, 1,3-dinitrobenzene, 4-nitroaniline, 2,4,6-trinitrotoluene, 1,4-dinitrobenzene
Nitroarenes | ToxAlerts | 3,5-Dinitroaniline, 3-nitroaniline, 1,3-dinitrobenzene, 4-nitroaniline, 2,4,6-trinitrotoluene, 1,4-dinitrobenzene
Nitroarenes | OncoLogic | 2,4,6-Trinitrotoluene^a^
Polynitroarenes | OECD QSAR Toolbox | 3,5-Dinitroaniline, 1,3-dinitrobenzene, 2,4,6-trinitrotoluene, 1,4-dinitrobenzene
Primary aromatic amine, hydroxyl amine and its derived esters | Toxtree | 3,5-Dinitroaniline, 3-nitroaniline, 1,3-dinitrobenzene, 4-nitroaniline
Primary aromatic amine, hydroxyl amine and its derived esters | OECD QSAR Toolbox | 3,5-Dinitroaniline, 3-nitroaniline, 4-nitroaniline
Primary aromatic amine, hydroxyl amine and its derived esters or amine generating group | ToxAlerts | 3,5-Dinitroaniline, 3-nitroaniline, 4-nitroaniline
Nitroaniline derivative | OECD QSAR Toolbox | 3,5-Dinitroaniline, 3-nitroaniline, 4-nitroaniline

a Identified as low–moderate or marginal alerts (shown as white cells in Table C-4, indicating results or alerts outside the applicability domain).

OECD = Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship; SA = structural alert.

## STEP 7 EVIDENCE INTEGRATION FOR SCREENING EVALUATION OF 3,5-DINITROANILINE CARCINOGENICITY

Table C-6 presents the data for multiple lines of evidence pertinent to the screening evaluation of the carcinogenic potential of 3,5-dinitroaniline.

Table C-6 Integration of Evidence for 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues

Evidence Streams | 3,5-Dinitroaniline; CASRN 618-87-1 | 1,3-Dinitrobenzene; CASRN 99-65-0 | 1,4-Dintrobenzene; CASRN 100-25-4 | 3-Nitroaniline; CASRN 99-09-2 | 4-Nitroaniline; CASRN 100-01-6 | 2,4,6-Trinitrotoluene; CASRN 118-96-7
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
Analogue selection and evaluation; (see Steps 1 and 2) | Target compound; contains: (1) one aromatic ring (benzene) substituted with (2) one amine group and two nitro groups on the ring, in a meta-substitution pattern, and (3) no other functional group | Contains: (1) one aromatic ring (benzene) substituted with (2) two nitro groups, in a meta-substitution pattern, and (3) no other functional group | Contains: (1) one aromatic ring (benzene) substituted with (2) two nitro groups, in a para-substitution pattern, and (3) no other functional group | Contains: (1) one aromatic ring (benzene) substituted with (2) one amine group and one nitro group on the ring, in a meta-substitution pattern, and (3) no other functional group | Contains: (1) one aromatic ring (benzene) substituted with (2) one amine group and one nitro group on the ring, in a para-substitution pattern, and (3) no other functional group | Contains: (1) one aromatic ring (toluene) substituted with (2) three nitro groups on the ring, and (3) no other functional group
Experimental genotoxicity data; (see Step 3) | Mutagenic in Salmonella; data for other endpoints not available | Mutagenic in Salmonella; limited evidence of clastogenicity in mammalian cells; caused DNA damage in rat germ cells in vitro; did not induce UDS in rat liver cells in vitro | Inconsistent evidence of weak mutagenicity in Salmonella; limited evidence of clastogenicity in mammalian cells in vitro; did not induce UDS in rat liver cells in vitro | Mutagenic in Salmonella; clastogenic in mammalian cells in vitro and in vivo; did not induce UDS in rat liver cells in vitro | Mutagenic in Salmonella; did not cause mutations in mammalian cells in vitro or Drosophila larvae; clastogenic in mammalian cells in vitro; did not induce UDS in rat liver cells in vitro; bound RNA in vitro | Mutagenic in Salmonella; limited and inconsistent findings for mutagenicity in mammalian cells; negative in rodents (in vivo) for clastogenic endpoints; did not induce UDS in mammalian cells in vitro or in vivo
ADME evaluation; (see Step 4) | ND; metabolic pathways identified for analogues with data are plausible | Common primary metabolic pathway with other analogues with data (nitroreduction followed by N-acetylation or ring hydroxylation) | Common primary metabolic pathway with other analogues with data (nitroreduction followed by N-acetylation or ring hydroxylation) | ND; metabolic pathways identified in analogues with data are plausible | Limited data; metabolic pathways identified in analogues with data are plausible | Common primary metabolic pathway with other analogues with data (nitroreduction followed by N-acetylation or ring hydroxylation)
Cancer data and MOA; (see Step 5) | ND | ND | ND | ND | Vascular tumors (hemangiomas and hemangiosarcomas) in male mice; Proposed MOA: Mutagenicity | Urinary bladder tumors in female rats, leukemia and/or malignant lymphoma of the spleen in female mice; MOA not established
Common structural alerts and SAR predictions; (see Step 6) | ALERTS; - Aromatic amine; - Aromatic nitro/nitro-aromatic; - Nitroarenes; - Polynitroarenes; - Primary aromatic amine, hydroxyl amine, and its derived esters; - Primary aromatic amine, hydroxyl amine, and its derived esters or amine generating group; - Nitroaniline derivative; SAR PREDICTIONS: Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Aromatic amine generating groups; - Aromatic nitro/nitro-aromatic; - Nitroarenes; - Polynitroarenes; - Primary aromatic amine, hydroxyl amine, and its derived esters; SAR PREDICTIONS: Concerns for mutagenicity and carcinogenicity in most models; low–moderate concern for carcinogenicity in OncoLogic and no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Aromatic amine generating groups; - Aromatic nitro/nitro-aromatic; - Nitroarenes; - Polynitroarenes; SAR PREDICTIONS: Concerns for mutagenicity and carcinogenicity in most models; marginal concern for carcinogenicity in OncoLogic and no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Aromatic amine; - Aromatic nitro/nitro-aromatic; - Nitroarenes; - Primary aromatic amine, hydroxyl amine, and its derived esters; - Primary aromatic amine, hydroxyl amine, and its derived esters or amine generating group; - Nitroaniline derivative; SAR PREDICTIONS: Concerns for mutagenicity and carcinogenicity in most models; low–moderate concern for carcinogenicity in OncoLogic and no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Aromatic amine; - Aromatic nitro/nitro-aromatic; - Nitroarenes; - Primary aromatic amine, hydroxyl amine, and its derived esters; - Primary aromatic amine, hydroxyl amine, and its derived esters or amine generating group; - Nitroaniline derivative; SAR PREDICTIONS: Concerns for mutagenicity in most models and concerns for carcinogenicity in some models; marginal concern for carcinogenicity in OncoLogic, no concerns for carcinogenicity in three VEGA models, and no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Aromatic nitro/nitro-aromatic; - Nitroarenes; - Polynitroarenes; SAR PREDICTIONS: Concerns for mutagenicity and carcinogenicity in most models; low–moderate concern for carcinogenicity in OncoLogic and no concern for nongenotoxic carcinogenicity in Toxtree

ADME = absorption, distribution, metabolism, excretion; DNA = deoxyribonucleic acid; MOA = mode of action; ND = no data; RNA = ribonucleic acid; SAR = structure-activity relationship; UDS = unscheduled DNA synthesis; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

## STEP 8 QUALITATIVE LEVEL OF CONCERN FOR 3,5-DINITROANILINE POTENTIAL CARCINOGENICITY

Table C-7 identifies the qualitative level of concern for potential carcinogenicity of 3,5-dinitroaniline based on the multiple lines of evidence described above. Because of the lack of information supporting carcinogenic portal-of-entry effects, the qualitative level of concern for this chemical is considered to be applicable to all routes of exposure.

Table C-7 Qualitative Level of Concern for Carcinogenicity of 3,5-Dinitroaniline (CASRN 618-87-1)

Level of Concern | Designation | Comments
Concern for potential carcinogenicity | Selected | 3,5-Dinitroaniline and its analogues all produce some evidence of genotoxicity, share common metabolic pathways, and have common structural alerts (aromatic nitro, nitroarenes, polynitroarenes) and SAR predictions. Only two analogues of 3,5-dinitroaniline have in vivo animal cancer data (4-nitroaniline and 2,4,6-trinitrotoluene); however, both report carcinogenic potential. Additionally, most SAR predictive tools show concern for mutagenicity and/or carcinogenicity. Based on available evidence, there is concern for potential carcinogenicity of 3,5-dinitroaniline.
Inadequate information for assigning qualitative level of concern | NS | NA

NA = not applicable; NS = not selected; SAR = structure-activity relationship.