# APPENDIX A SCREENING NONCANCER PROVISIONAL REFERENCE VALUES

Due to the lack of evidence described in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional toxicity values for 3,5-dinitroaniline. However, some information is available for this chemical, which although insufficient to support deriving a provisional toxicity value under current guidelines, may be of use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with the derivation of an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

## APPLICATION OF AN ALTERNATIVE ANALOGUE APPROACH

The analogue approach allows for the use of data from related compounds to calculate screening values when data for the compound of interest are limited or unavailable. Details regarding searches and specific methods for the tiered analogue analysis applied herein are presented in Wang et al. (2012). Three types of potential analogues (structural, metabolic, and toxicity-like) are identified to facilitate the final analogue chemical selection. The analogue approach may or may not be route specific or applicable to multiple routes of exposure. All the available information is considered together as part of the final weight-of-evidence (WOE) approach to select the most suitable analogue both toxicologically and chemically.

An initial analogue search focused on identifying structurally related chemicals with toxicity values available in the Integrated Risk Information System (IRIS), PPRTV, Agency for Toxic Substances and Disease Registry (ATSDR), or California Environmental Protection Agency (CalEPA) databases to take advantage of the well-characterized chemical-class information. A total of 14 structurally related chemicals with oral and/or inhalation toxicity values are available as potential analogues for 3,5-dinitroaniline; structures of these chemicals are shown in Table A-1.

In selecting potential candidate analogues for this compound, chemicals of the following classes were initially considered: nitroanilines, dinitroaniline herbicides, trinitrobenzenes, dinitrobenzenes, trinitrotoluenes, dinitrotoluenes, and benzenediamines. Chemicals in these particular classes have two or three nitro or amino substituents on a benzene ring, and no other substituents apart from a methyl group. The nitro and amino substituents are likely important to the putative toxicological mode of action (MOA) for 3,5-dinitroaniline because many aromatic compounds with these substituents primarily induce methemoglobinemia and its sequelae of hematologic and splenic effects (Bingham and McGowan, 2012). Structure, reactivity, metabolism, and toxicity data for chemicals in these classes were examined to determine whether the list of candidate analogues could be further narrowed. Based on the available data and expert judgement, benzenediamines, dinitrotoluenes, and compounds with nitrogen-containing substituents in the ortho position to each other were omitted from the list of candidate analogues (see shaded structures in Table A-1), as described below.

Table A-1 Structures of Chemicals with Toxicity Values Initially Considered for Candidate Analogues^a^

3,5-Dinitroaniline (target compound; 618-87-1)
structure diagram
Dinitroaniline herbicides (nitro and alkylated amino groups)
2,6-Dinitro-N,N-dipropyl-4-isopropyl aniline (isopropalin; 33820-53-0) | 3,4-Dimethyl-2,6-dinitro-N-(1-ethylpropyl)aniline (pendimethalin; 40487-42-1) | 2,6-Dinitro-N,N-dipropyl-4-trifluoroaniline (trifluralin; 1582-09-8)
structure diagram; - Alkyl substituent on amine affects uptake and distribution relative to the target compound, which is an unsubstituted amine | structure diagram; - Alkyl substituent on amine affects uptake and distribution relative to the target compound, which is an unsubstituted amine; - Metabolism data indicate cyclization reaction (to form benzimidazoles groups) which is not possible for target compound | structure diagram; - Alkyl substituent on amine affects uptake and distribution relative to the target compound, which is an unsubstituted amine; - Metabolism data indicate cyclization reaction (to form benzimidazoles groups), which is not possible for target compound
Nitroanilines (nitro and amino groups)
2-Nitroaniline (88-74-4) | 3-Nitroaniline (99-09-2) | 4-Nitroaniline (100-01-6)
structure diagram; - Ortho amino substituent causes steric metabolic hindrance | structure diagram | structure diagram
Nitrobenzenes (nitro groups only)
1,3,5-Trinitrobenzene (99-35-4) | 1,3-Dinitrobenzene (99-65-0)
structure diagram | structure diagram
Nitrotoluenes (nitro and methyl groups)
2,4-Dinitrotoluene (121-14-2) | 2,6-Dinitrotoluene (606-20-2) | 2,4,6-Trinitrotoluene (118-96-7)
structure diagram; - Primary metabolic pathway forms carboxylic acid (methyl group oxidation); - Not possible for target compound | structure diagram; - Primary metabolic pathway forms carboxylic acid (methyl group oxidation); - Not possible for target compound | structure diagram; - Retained because methyl group oxidation is NOT a primary metabolic pathway
Benzenediamines (amino groups only)
1,2-Phenylenediamine (95-54-5) | 1,3-Benzenediamine (108-45-2) | 1,4-Benzenediamine (106-50-3)
structure diagram; - Lacks nitro substituent (lower electron withdrawing potential); - Available metabolism data indicate formation of N-acetylated derivatives in liver/urine, which may contribute to different critical effects than those predicted for target compound | structure diagram; - Lacks nitro substituent (lower electron withdrawing potential); - Available metabolism data indicate formation of N-acetylated derivatives in liver/urine, which may contribute to different critical effects (e.g. liver) than those predicted for target compound | structure diagram; - Lacks nitro substituent (lower electron withdrawing potential); - Available metabolism data indicate formation of N-acetylated derivatives in liver/urine, which may contribute to different critical effects than those predicted for target compound

a Shading shows chemical classes omitted from consideration (see text for discussion).

Among dinitroanilines, toxicity values are available for the dinitroaniline herbicides isopropalin, pendimethalin, and trifluralin. However, these compounds include alkyl substituents on the amine that are expected to affect uptake and distribution (e.g., increased hydrophobicity) in the body relative to the unsubstituted amine of 3,5-dinitroaniline. In addition, metabolism data available for two of these compounds (pendimethalin and trifluralin) show cyclization reactions involving the alkyl groups that form benzimidazole groups (IARC, 1991; Zulalian, 1990); corresponding chemical reactions are not possible for 3,5-dinitroaniline, so the dinitroaniline herbicides were not considered further as candidate analogues.

Benzenediamines are the only chemical class among the candidate analogue classes that lack a nitro substituent. Because this class of chemicals lacks a nitro group, the benzenediamines exhibit lower electron-withdrawing potential than chemicals with nitro groups. Sabbioni and Jones (2002) noted that compounds with strong electron-withdrawing groups (including dinitrobenzenes, trinitrobenzenes, and trinitrotoluenes) can be reduced in erythrocytes, providing another site of bioactivation to the hydroxylamino intermediate that interacts with hemoglobin to produce methemoglobin. Available metabolism data on benzenediamines indicate that the primary metabolites in the liver and urine are N-acetylated derivatives [Nakao et al. (1980) as cited in ECHA (2015a); Lam and Bisgaard (1989) as cited in HSDB (2009)], and N-acetylation is a detoxification pathway for methemoglobin induction (Sabbioni and Jones, 2002). Consistent with this observation, liver effects represent the critical/most sensitive effect(s) used by IRIS to derive the chronic oral reference dose (RfD) for 1,3-benzenediamine (U.S. EPA, 2002b) rather than blood or splenic effects. For these reasons, benzenediamines were not considered further.

Dinitrotoluenes were omitted from consideration because the primary metabolic pathway for these compounds is methyl group oxidation (ATSDR, 2016) leading to the formation of a carboxylic acid, and this pathway is not possible for 3,5-dinitroaniline. Trinitrotoluenes were retained for consideration, however, as methyl group oxidation is not a primary metabolic pathway for these compounds (ATSDR, 1995b). Finally, data on the metabolism of aromatic nitro and amino compounds indicate that the position of the substituents on the ring affects metabolism to the hydroxylamino intermediates, with substituents in the ortho position to the nitro or amino group inhibiting bioactivation (Sabbioni and Jones, 2002). This is not likely due to electronic effects, but rather steric effects that decrease the rate of reaction of ortho substituents. The inhibition of bioactivation is borne out by available data on methemoglobinemia in rats treated orally with single doses of nitroanilines; 2-nitroaniline was inactive (as was the ortho-positioned 2,4-dinitroaniline, the only dinitroaniline tested), whereas 3- and 4-nitroaniline (non-ortho positioned) induced statistically significant increases in methemoglobin within 1 hour of dosing (SOCMA, 2000). Thus, candidate analogues with amino or nitro groups in the ortho position to another nitrogen-containing substituent (i.e., 2-nitroaniline) were not considered further, while those with nitrogen-containing substituents in the meta or para positions were included as candidate analogues.

### Structural Analogues

Following the initial selection process outlined above, five structural analogues to 3,5-dinitroaniline with oral and/or inhalation noncancer reference values remained: 3-nitroaniline, 4-nitroaniline, 1,3,5-trinitrobenzene, 1,3-dinitrobenzene, and 2,4,6-trinitrotoluene (TNT). As described in Wang et al. (2012), structural similarity for analogues was evaluated using the Organisation for Economic Co-operation and Development (OECD) Quantitative Structure-Activity Relationship (QSAR) Toolbox (OECD, 2018) and the National Library of Medicine’s (NLM’s) ChemIDplus database (ChemIDplus, 2018). Table A-2 summarizes the analogues’ physicochemical properties and structural similarity scores. Physicochemical properties indicate that 3,5-dinitroaniline and the remaining candidate analogues are all water soluble and appear likely to be bioavailable via the oral route. Although the low vapor pressures and Henry’s law constants of 3,5-dinitroaniline and the candidate analogues suggest limited potential for exposure via inhalation, the compounds can be inhaled if they are aerosolized or particle-bound, and once inhaled, absorption via the respiratory tract is likely. The ChemIDplus similarity scores for the remaining candidates exhibited a range between 56% for 3-nitroaniline and 86% for 1,3,5-trinitrobenzene. A ChemIDplus similarity score was not available for 4-nitroaniline. The OECD similarity scores ranged between 52.2% (4-nitroaniline) and 78.6% (1,3,5-trinitrobenzene). The similarity score predictions were similar across both tools. The identified candidate structural analogues all share similarities in functional groups (nitro and amino substituents), as well as similar physicochemical properties (detailed in Table A-2). In summary, any of these analogues may be considered an appropriate structural analogue for 3,5-dinitroaniline under the Wang et al. (2012) methodology.

Table A-2 Physicochemical Properties of 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues^a^

Type of Data | 3,5-Dinitroaniline (target) | 3-Nitroaniline | 4-Nitroaniline | 1,3,5-Trinitrobenzene | 1,3-Dinitrobenzene | 2,4,6-Trinitrotoluene
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
CASRN | 618-87-1 | 99-09-2 | 100-01-6 | 99-35-4 | 99-65-0 | 118-96-7
Molecular weight (g/mol) | 183 | 138 | 138 | 213 | 168 | 227
ChemIDplus similarity score (%)^b^ | 100 | 56 | NV | 86 | 82 | 72
OECD similarity score (%)^c^ | 100 | 60.9 | 52.2 | 78.6 | 72 | 62.1
Melting point (°C) | 162 | 113 | 148 | 122 | 90 | 80
Boiling point (°C) | 398 | 306 | 297 | 315 | 296 | 240
Vapor pressure (mm Hg at 25°C) | 1.39 × 10^−5^ (predicted average) | 9.56 × 10^−5^ | 3.2 × 10^−6^ | 6.44 × 10^−6^ | 9 × 10^−4^ | 8.02 × 10^−6^
Henry’s law constant (atm-m^3^/mole at 25°C) | 4.34 × 10^−8^ (predicted average) | 7.91 × 10^−9^ | 1.26 × 10^−9^ | 3.96 × 10^−7^ (estimated) | 4.9 × 10^−8^ | 3.92 × 10^−7^
Water solubility (mg/L) | 7.08 × 10^−3^ | 7.95 × 10^−3^ | 4.76 × 10^−3^ | 1.29 × 10^−3^ | 3.16 × 10^−3^ | 5.67 × 10^−4^
Octanol water partition coefficient (log K_ow_) | 1.89 | 1.37 | 1.39 | 1.18 | 1.49 | 1.60
Acid dissociation constant (pKa) (for protonated compound) | 0.3^d^ | 2.60 | 1.03 | NV | NV | NV

a Data represent experimental average values as reported on the U.S. EPA’s CompTox Chemicals Dashboard unless otherwise specified (CASRN 618-87-1; https://comptox.epa.gov/dashboard/dsstoxdb/results?search=618-87-1#properties. Accessed July 15, 2020).

b ChemIDplus advanced similarity scores (ChemIDplus, 2018).

c OECD QSAR Toolbox (Version 4.1) Dice.

d U.S. EPA (2012).

NV = not available; OECD = Organisation for Economic Co-operation and Development.

### Metabolic Analogues

No toxicokinetic information was located for 3,5-dinitroaniline. Although there were no quantitative data on the toxicokinetics of the candidate analogue compounds after inhalation exposure, there is qualitative evidence for uptake of 1,3-dinitrobenzene, 1,3,5-trinitrobenzene, and TNT in humans believed to be occupationally exposed by inhalation (ATSDR, 1995a, b). Oral absorption, distribution, metabolism, and excretion information are available for all candidate analogues (see Table A-3) except 3-nitroaniline. As Table A-3 shows, 4-nitroaniline, 1,3-dinitrobenzene, and TNT are well absorbed after oral exposure (59 to >80% based on urinary excretion). For 1,3,5-trinitrobenzene, at least 24% was excreted in the urine after oral exposure; however, total recovery was not reported so it is uncertain whether the balance was retained or if overall recovery of radioactivity was low. Studies examining tissue distribution of the candidate analogues indicate little tissue accumulation and no preferential deposition in any particular tissue (U.S. EPA, 2009a, b, 1997; ATSDR, 1995a, b).

The aromatic nitro and amino compounds are well-studied chemical classes with a relatively well-defined MOA for noncancer toxicity [reviewed by Bingham and McGowan (2012); Sabbioni and Jones (2002)]. In general, these compounds induce methemoglobinemia via hydroxylamino intermediates formed during reduction of a nitro group and/or N-hydroxylation of an amino group (Bingham and McGowan, 2012). No studies identifying the primary metabolites of 3- or 4-nitroaniline were identified in the available literature. Available in vivo and in vitro data on metabolism of the other candidate analogues confirmed that the major pathways are nitroreduction, N-hydroxylation, ring-hydroxylation, N-acetylation, and sulfate or glucuronic acid conjugation of phenolic or N-hydroxylamine intermediates (U.S. EPA, 1997; ATSDR, 1995a, b). Nitroreduction may occur in the gut (via resident microbiota), liver, or erythrocytes (Sabbioni and Jones, 2002). N-Acetylation may occur in the liver or in the bladder, where the acidic pH subsequently promotes formation of nitrenium ions that form deoxyribonucleic acid (DNA) adducts (Sabbioni and Jones, 2002). Metabolism by other pathways occurs primarily in the liver [reviewed by Bingham and McGowan (2012); Sabbioni and Jones (2002)].

Identification of the hepatic and urinary metabolites produced by the candidate analogues with suitable data (see Table A-3) indicates that these compounds are generally metabolized as follows. 1,3,5-Trinitrobenzene undergoes sequential nitroreduction, yielding dinitroanilines (including 3,5-dinitroaniline, the target compound), diaminonitrobenzene, and triaminobenzene derivatives (U.S. EPA, 1997; ATSDR, 1995a). Similarly, 1,3-dinitrobenzene undergoes sequential nitroreduction followed by N-acetylation or ring hydroxylation; some of the resulting metabolites are subsequently conjugated with sulfate or glucuronic acid (HSDB, 2012; ATSDR, 1995a; Cossum and Rickert, 1985). Finally, TNT undergoes sequential nitroreduction (yielding amino dinitrotoluene or diamino nitrotoluene derivatives) as well as N- and ring-hydroxylation reactions (yielding hydroxylamino, dinitrotoluene, or aminodinitro cresol derivatives) (ATSDR, 1995b). Again, there were no experimental toxicokinetic data for 3-nitroaniline, and the metabolites for 4-nitroaniline were not fully identified. Taken together, the available metabolism data suggest the involvement of comparable pathways based on structural inference for the candidate analogues presented in Table A-3, making them plausible metabolic analogues for the target.

Table A-3 Comparison of Available ADME Data for 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues

3,5-Dinitroaniline (target) | 3-Nitroaniline | 4-Nitroaniline | 1,3,5-Trinitrobenzene | 1,3-Dinitrobenzene | 2,4,6-Trinitrotoluene
structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
Absorption after oral exposure
ND | ND | Oral absorption in rats was ≥79% based on elimination via urine and expired air (see below) | Oral absorption in rats was ≥24–39% based on urine and expired air (see below); fecal elimination was low, and it is uncertain whether the balance of the dose was retained in the body or if overall recovery was low | Oral absorption in rabbits was ≥80% based on elimination via urine (see below) | Oral absorption was ≥59% in rats, mice, and dogs, based on radioactivity in urine (see below)
Distribution
ND | ND | Rats exposed orally:; Tissue radioactivity ranged from 0.1–0.36% of dose 72 h postdosing; Rats exposed intravenously:; Highest peak concentration in individual tissues (% dose/g tissue) as follows:; Blood: 0.50; Urinary bladder: 3.33; Kidney: 1.79; Liver: 0.84; Lung: 0.73; Heart: 0.66; All tissue concentrations peaked 15 min postdosing | Rats exposed orally:; Highest radioactivity in liver, kidney, skin, and lungs (0.02–0.03% of dose/g tissue 96 h postdosing) | ND | Rats exposed orally:; Highest radioactivity in liver, skeletal muscle, blood, and fat (<0.1–5.4% of dose 24 h postdosing)
Metabolites
ND | ND | Rats exposed intravenously:; Urinary:; Nine unidentified metabolites; 56% of urinary radioactivity consisted of 2 sulfate conjugates and 3.5% was unmetabolized parent compound; 7 of the 9 metabolites were detected in bile | Rats exposed orally:; Urinary:; 3,5-Dinitroaniline; 1,3-Diamino-5-nitrobenzene; 1,3,5-Triaminobenzene; Fecal:; 1,3-Diamino-5-nitrobenzene; 1,3,5-Triaminobenzene; Liver microsomes in vitro:; 1,3-Diamino-5-nitrobenzene; 3,5-Dinitroaniline | Rats exposed orally:; Urinary:; 3-Aminoacetanilide (22%); 4-Acetamido phenyl sulfate (6%); 1,4-Diacetamido benzene (7%); 3-Nitroaniline-N-glucuronide (4%); Hepatocytes and microsomes in vitro:; 3-Nitroaniline; Microsomal metabolism mediated by NADPH-CYP450 reductase.; Rabbits exposed orally:; Urinary:; 3-Nitroaniline and 1,3-Benzenediamine (35%); 2,4-Diaminophenol (31%); 2-Amino-4-nitrophenol (14%); 4-Amino-2-nitrophenol (2%); 30% of the metabolites were conjugated with glucuronic acid and 6% with sulfate | Human:; Urinary:; 2-Amino-4,6-dinitrotoluene; 4-Amino-2,6-dinitrotoluene; 2,4-Diamino-6-nitrotoluene; 4-Hydroxyl amino-2,6-dinitrotoluene; 4-Amino-2,6-dinitro-m-cresol; Similar metabolites identified in rat, mouse, rabbit, and dog urine
Excretory pattern
ND | ND | Rats exposed orally (% dose in 3 d):; Urine: 75–96; Feces: 4–14; Expired air: 0.01–0.07; Biliary excretion in 4 h after intravenous dose: 19% | Rats exposed orally (% dose):; Urine: 21–36 (in 4 d); Feces: 4 (in 4 d); Expired air: 3–5 (in 2 d); It is uncertain whether the balance of the dose was retained in the body or if overall recovery was low because the study was reported only in abstract form [Reddy and Gunnarson (1993) as cited in U.S. EPA (1997)] | Rabbits exposed orally (% dose in 2 d):; Urine: 81; Feces: 0.3–5.2; Expired air: ND | Rats, mice, dogs, and rabbits exposed orally (% dose):; Urine: 59–74 (in 24 h)
References
NA | NA | Chopade and Matthews (1984) as cited in U.S. EPA (2009b) | ATSDR (1995a); U.S. EPA (1997); U.S. EPA (2009a) | ATSDR (1995a) | ATSDR (1995b)

ADME = absorption, distribution, metabolism, excretion; CYP450 = cytochrome P450; NA = not applicable; NADPH = reduced form of nicotinamide adenine dinucleotide phosphate; ND = no data.

Excretion of the candidate analogues following oral exposure (apart from 3-nitroaniline, for which there are no data) is primarily via the urine as tested in rats, mice, dogs, or rabbits in studies employing radioactive compounds; between 59 and 96% of an orally administered dose of 4-nitroaniline, 1,3-dinitrobenzene, or TNT is excreted in urine, and 21–36% of an oral dose of 1,3,5-trinitrobenzene is excreted in the urine (U.S. EPA, 2009b, 1997; ATSDR, 1995a, b). Small amounts of radioactivity are excreted in feces after exposure to 1,3,5-trinitrobenzene and 1,3-dinitrobenzene. Between 4 and 14% of an oral dose of 4-nitroaniline was excreted in feces of rats, and biliary excretion of this compound has been demonstrated (U.S. EPA, 2009b). There are no data on fecal or biliary excretion of TNT (ATSDR, 1995b).

In summary, although the most proximate metabolic analogue is 1,3,5-trinitrobenzene [because 3,5-dinitroaniline is a metabolite of 1,3,5-trinitrobenzene in rats exposed orally (U.S. EPA, 1997; ATSDR, 1995a)], metabolism of the three remaining candidate analogues occurs via pathways (including bioactivation to hydroxylamine intermediates) that are likely to be relevant to 3,5-dinitroaniline. There are no experimental toxicokinetic data for 3-nitroaniline. Thus, 4-nitroaniline, 1,3,5-trinitrobenzene, 1,3-dinitrobenzene, and 2,4,5-trinitrotoluene are plausible metabolic analogues.

### Toxicity-Like Analogues

No toxicity data are available for 3,5-dinitroaniline apart from in vitro genotoxicity studies. Tables A-4, A-5, and A-6 summarize available oral subchronic toxicity values, oral chronic toxicity values, and inhalation subchronic and chronic toxicity values (respectively) for the compounds identified as candidate analogues.

As discussed earlier, methemoglobin induction is a consistently observed effect of aromatic nitro and amino compounds in laboratory animal studies (Bingham and McGowan, 2012). This effect occurs when nitro compounds undergo nitroreduction and/or when N-hydroxylamines are oxidized to nitroarenes in the blood, leading to oxidation of the ferrous ion in hemoglobin which prevents the hemoglobin from combining reversibly with oxygen (Bingham and McGowan, 2012; Sabbioni and Jones, 2002). Adverse sequelae of methemoglobinemia include hematologic effects such as decreased red blood cell (RBC) count and hemoglobin, leading to compensatory hematopoiesis and, as hemoglobin is degraded, hemosiderin deposition in the liver and/or spleen. Common comorbidities include increased splenic weight and extramedullary hematopoiesis.

Animals exposed to each of the candidate analogues exhibited signs of methemoglobin induction following both oral and inhalation exposure. Of note, only a single analogue (4-nitroaniline) has a published inhalation toxicity value (see Table A-6). Additionally, as shown in Tables A-4 through A-6, either methemoglobinemia or its related effects were the critical endpoints in the rat studies used to derive subchronic and chronic oral and inhalation toxicity values for all of the candidate analogues other than TNT. For TNT, hepatic effects (pathology) in dogs were the critical endpoint for deriving the chronic RfD (0.5 mg/kg-day); however, at higher doses, increased methemoglobin (8 or 32 mg/kg-day) and hemosiderin deposition in the liver (2 mg/kg-day) were observed. Related hematologic effects were observed in other species, including rats and mice following TNT exposure (U.S. EPA, 2002a). The differences in critical effect may be related to differences in species or metabolism of TNT. While the critical effects observed with 4-nitroaniline inhalation exposure were consistent with those observed orally and the putative mode of action for this class of chemicals, it does provide greater uncertainty because of the lack of inhalation data for other analogues. Thus, the available data show clear commonalities in the toxic effects for all five analogues, providing support for the inference that 3,5-dinitroaniline would behave in a similar manner.

Table A-4 Comparison of Available Subchronic Oral Toxicity Data for 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues

Type of Data | 3,5-Dinitroaniline; CASRN 618-87-1 (target) | 3-Nitroaniline; CASRN 99-09-2 | 4-Nitroaniline; CASRN 100-01-6 | 1,3,5-Trinitrobenzene; CASRN 99-35-4 | 1,3-Dinitrobenzene; CASRN 99-65-0 | 2,4,6-Trinitrotoluene; CASRN 118-96-7
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
POD (mg/kg-d) | NV | 15 | 0.95 | NV | NV | NV
POD type | NV | LOAEL | BMDL_1SD_ | NV | NV | NV
UF_C_ | NV | 10,000 (UF_A_, UF_D_, UF_H_, UF_L_, UF_S_) | 100 (UF_A_, UF_H_) | NV | NV | NV
RfD (mg/kg-d) | NV | 1 × 10^−3^; (screening due to UF_C_ >3,000) | 1 × 10^−2^ | NV | NV | NV
Critical effects | NV | Decreased RBCs and hemoglobin; histopathology of spleen (hemosiderin deposition, extramedullary hematopoiesis, congestion) and bone marrow (erythroid hyperplasia) | Increased methemoglobin | NV | NV | NV
Other effects | NV | Methemoglobinemia; increased absolute and relative spleen, liver, and kidney weights; decreased absolute and relative testes weight; hepatocyte swelling and hepatic hemosiderin deposition and extramedullary hematopoiesis; renal lipofuscin deposition; reduced spermatogenesis, multinucleated giant cell formation in the testes, and absence of spermatozoa in the epididymis | Decreased RBCs, hematocrit, hemoglobin, mean corpuscular volume, and mean corpuscular hemoglobin; splenic congestion, hemosiderosis, and extramedullary hematopoiesis | NV | NV | NV
Species | NV | Rat | Rat | NV | NV | NV
Duration | NV | 28 d | 90 d | NV | NV | NV
Route (method) | NV | Oral (gavage) | Oral (gavage) | NV | NV | NV
Dosing levels (critical study) | NV | 0, 15, 50, 170 mg/kg-d | 0, 3, 10, 30 mg/kg-d | NV | NV | NV
Additional toxicity data from other studies | NV | Hepatomegaly, enlarged and dark spleens, and difficult labor with litter losses in reproductive/developmental toxicity study | Increased absolute and relative spleen weights and hemosiderosis of hepatic Kupffer cells in mice exposed subchronically; In developmental studies: mortality and body-weight loss in rabbit does; decreased rat fetal weight; malformations of the tail, digits, and kidneys of rat pups | Decreased body-weight gain; increased methemoglobin and reticulocytes, decreased RBCs and hemoglobin; increased relative liver, spleen, and brain weights; decreased testes weight; spleen and bone marrow erythroid cell hyperplasia; seminiferous tubule degeneration; renal hyaline droplets, tubular degeneration, and mineralized foci (mice exposed subchronically) (U.S. EPA, 1997) | NV | NV
Source | NV | Onodera (date unknown) as cited in U.S. EPA (2009a) | Monsanto Co. (1981) as cited in U.S. EPA (2009b) | U.S. EPA (1997) | NV | NV

BMDL = benchmark dose lower confidence limit; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; NV = not available; POD = point of departure; RBC = red blood cell; RfD = oral reference dose; SD = standard deviation; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Table A-5 Comparison of Available Chronic Oral Toxicity Data for 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues

Type of Data | 3,5-Dinitroaniline; CASRN 618-87-1 | 3-Nitroaniline; CASRN 99-09-2 | 4-Nitroaniline; CASRN 100-01-6 | 1,3,5-Trinitrobenzene; CASRN 99-35-4 | 1,3-Dinitrobenzene; CASRN 99-65-0 | 2,4,6-Trinitrotoluene; CASRN 118-96-7
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
POD (mg/kg-d) | NV | NV | 0.37 | 2.68 | 0.40 | 0.5
POD type | NV | NV | BMDL_1SD_ | NOAEL | NOAEL | LOAEL
UF_C_ | NV | NV | 100 (UF_A_, UF_H_) | 100 (UF_A_, UF_H_) | 3,000 (UF_A_, UF_D_, UF_H_, UF_S_) | 1,000 (UF_A_, UF_H_, UF_L_, UF_S_)
RfD (mg/kg-d) | NV | NV | 4 × 10^−3^ | 3 × 10^−2^ | 1 × 10^−4^ | 5 × 10^−4^
Critical effects | NV | NV | Increased methemoglobin | Methemoglobinemia and spleen erythroid cell hyperplasia | Increased spleen weight (absolute or relative not reported) | Hepatocyte swelling (trace to mild severity)
Other effects | NV | NV | Increased absolute and relative spleen weight; hemosiderosis in liver and spleen | Decreased body weight; decreased hemoglobin and RBCs; seminiferous tubule degeneration; increased relative brain, spleen, liver, and/or kidney weights | Decreased body-weight gain in females, decreased hemoglobin and testicular atrophy in males, and hemosiderin deposits in spleen of both sexes | Increased methemoglobin; increased absolute and relative liver weight, cirrhosis, and hemosiderosis of the liver at higher doses
Species | NV | NV | Rat | Rat | Rat | Dog
Duration | NV | NV | 2 yr | 2 yr | 16 wk | 25 wk
Route (method) | NV | NV | Oral (gavage) | Oral (diet) | Oral (drinking water) | Oral (gelatin capsule)
Dosing levels (critical study) | NV | NV | 0, 0.25, 1.5, 9.0 mg/kg-d | M: 0, 0.23, 2.68, 13.31 mg/kg-d^a^; F: 0, 0.22, 2.64, 13.44 mg/kg-d)^b^ | 0, 0.4, 1.1, 2.7 mg/kg-d^b^ | 0, 0.5, 2, 8, 32 mg/kg-d
Additional toxicity data from other studies | NV | NV | Increased sulfhemoglobin, reduced hematocrit and RBCs, increased reticulocytes, mean corpuscular hemoglobin, and mean corpuscular hemoglobin concentration; increased absolute and relative spleen and liver weights; bone marrow hypercellularity, hemosiderosis of hepatic Kupffer cells, splenic congestion, and splenic extramedullary hematopoiesis; hemangiomas, and hemangiosarcomas in mice exposed chronically; In developmental studies: mortality and body-weight loss in rabbit does; decreased rat fetal weight; malformations of the tail, digits, and kidneys of rat pups | Reduced numbers of motile sperm and splenic hemosiderosis in rat reproductive toxicity study; decreased maternal body weight, reduced fetal weight and crown-rump length, and increased incidence of skeletal variation in rat developmental toxicity study | Mortality, decreased spermatogenesis, reduced testicular weight in 8-wk rat study; ataxia, paresis equilibrium loss, muscle rigidity, absence of sperm in testis and epididymis cauda; decreased epididymis weight; and infertility in 12-wk rat study (U.S. EPA, 2005b; ATSDR, 1995a) | Anemia and hepatomegaly in mice; testicular degeneration and splenic effects in rats; urinary bladder papilloma and carcinoma in female rats; reported toxic effects in humans include cataracts, aplastic anemia, hepatitis, hepatomegaly, and liver cancer (U.S. EPA, 2002a; ATSDR, 1995b)
Source | NV | NV | Nair et al. (1990) as cited in U.S. EPA (2009b) | Reddy et al. (1996) as cited in U.S. EPA (1997) | Cody et al. (1981) as cited in U.S. EPA (2005b) | U.S. DOD (1983) as cited in U.S. EPA (2002a); Levine et al. (1990) as cited in ATSDR (1995b)

a Study authors report doses as 0, 5, 60, and 300 ppm diet; these were converted to dosages as reported by Reddy et al. (1996) as cited in U.S. EPA (1997).

b Study authors report doses as 0, 3, 8, and 20 ppm drinking water. Drinking water concentrations were converted to dosages by investigators in Cody et al. (1981) as cited in U.S. EPA (2005b).

BMDL_1SD_ = benchmark dose lower confidence limit, one standard deviation; F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); NOAEL = no-observed-adverse-effect level; NV = not available; POD = point of departure; RBC = red blood cell; RfD = reference dose; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Table A-6 Comparison of Available Subchronic and Chronic Inhalation Toxicity Data for 3,5-Dinitroaniline (CASRN 618-87-1) and Candidate Analogues

Type of Data | 3,5-Dinitroaniline; CASRN 618-87-1 | 3-Nitroaniline; CASRN 99-09-2 | 4-Nitroaniline; CASRN 100-01-6 | 1,3,5-Trinitrobenzene; CASRN 99-35-4 | 1,3-Dinitrobenzene; CASRN 99-65-0 | 2,4,6-Trinitrotoluene; CASRN 118-96-7
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
POD (mg/m^3^) | NV | NV | 1.7 | NV | NV | NV
POD type | NV | NV | BMCL_1SD_ (HEC) | NV | NV | NV
Subchronic UF_C_ | NV | NV | 100 (UF_A_, UF_D_, UF_H_) | NV | NV | NV
Subchronic RfC (mg/m^3^) | NV | NV | 2 × 10^−2^ | NV | NV | NV
Chronic UF_C_ | NV | NV | 300 (UF_A_, UF_D_, UF_H_, UF_S_) | NV | NV | NV
Chronic RfC (mg/m^3^) | NV | NV | 6 × 10^−3^ | NV | NV | NV
Critical effects | NV | NV | Increased methemoglobin | NV | NV | NV
Other effects | NV | NV | Polychromasia and anisocytosis of RBCs; increased WBCs; increased absolute and relative spleen weights; hemosiderosis and extramedullary hematopoiesis of the spleen | NV | NV | NV
Species | NV | NV | Rat | NV | NV | NV
Duration | NV | NV | 4 wk | NV | NV | NV
Route (method) | NV | NV | Inhalation (aerosol) | NV | NV | NV
Dosing levels (critical study) | NV | NV | 0, 10, 32, 80 mg/m^3^ | NV | NV | NV
Additional toxicity data from other studies | NV | NV | Decreased body weight; hematologic effects consistent with hemolytic anemia, methemoglobinemia, and compensatory hematopoiesis; splenic congestion; lymphoid cell atrophy of the spleen and thymus (2-wk study in rats) | NV | NV | NV
Source | NV | NV | Nair et al. (1986) as cited in U.S. EPA (2009b) | NV | NV | NV

BMCL = benchmark concentration lower confidence limit; HEC = human equivalent concentration; NV = not available; POD = point of departure; RBC = red blood cell; RfC = inhalation reference concentration; SD = standard deviation; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor; WBC = white blood cell.

### Weight-of-Evidence Approach

A WOE approach is used to evaluate information from candidate analogues as described by Wang et al. (2012). Commonalities in structural/physicochemical properties, toxicokinetics, metabolism, toxicity, or MOA between candidate analogues and chemical(s) of concern are identified. Emphasis is given to toxicological and/or toxicokinetic similarity over structural similarity. Analogues are excluded if they do not have commonality or demonstrate significantly different physicochemical properties and toxicokinetic profiles that set them apart from the pool of analogues and/or chemical(s) of concern. From the remaining analogues, the most appropriate analogue (most biologically or toxicologically relevant analogue chemical) with the highest structural similarity and/or most conservative toxicity value is selected.

The available data provide concordance across structural, metabolism, and toxicity lines of evidence. The functional groups that are shared by 3,5-dinitroaniline and the analogues (nitro and amino substituents) have been associated with primary target organ toxicities, including methemoglobinemia and related toxicities for this group of chemicals via metabolic bioactivation. The available data suggest commonalities in the toxicokinetics and toxicity of the five candidate analogues. Among those with toxicokinetic data, all are absorbed after oral exposure and primarily excreted in the urine. The aromatic nitro compounds are a well-studied chemical class for which the proximal toxicant for methemoglobinemia is believed to be the hydroxylamine intermediates. Available in vivo and in vitro data on metabolism of the candidate analogues confirms that the major pathways are nitroreduction, N-hydroxylation and ring-hydroxylation, N-acetylation, and sulfate or glucuronic acid conjugation of phenolic or N-hydroxylamine intermediates. Although 1,3,5-trinitrobenzene undergoes sequential nitroreduction to yield 3,5-dinitroaniline, the efficiency of this pathway and the potential involvement of other pathways is unknown. In addition, toxicity data on the candidate analogues confirm methemoglobinemia as the most sensitive critical effect for 4-nitroaniline and 1,3,5-trinitrobenzene. Increased spleen weight, a comorbidity of methemoglobinemia, was the critical effect for 1,3-dinitrobenzene. 3-Nitroaniline had a critical effect of decreased red blood cells and hemoglobin, as well as spleen histopathology changes (hemosiderin deposition) and bone marrow pathology changes (erythroid hyperplasia), and, at higher doses, methemoglobinemia, increased spleen weight, liver pathology (hepatocyte swelling, hepatic hemosiderin disposition, and extramedullary hematopoiesis), and other effects. TNT exhibited hematologic effects (e.g., increased methemoglobin) at higher doses than the liver effects used as the basis for the chronic RfD. Although the specific critical effect was distinct among analogues, the constellation of toxic effects, including splenic and hepatic effects as well as effects on hematology (methemoglobinemia, red blood cells), is consistent, and there are conserved pathways that contribute to these effects. The observed differences are likely due to differences in exposure routes, species, and experimental designs that were used across principal studies. Thus, the available data show clear commonalities in the structure, metabolic pathways, and the toxicological effects for the candidate analogues, providing support for the inference that 3,5-dinitroaniline could be metabolized by the same pathways and exhibit similar toxicity.

For 3,5-dinitroaniline, no metabolism or toxicity data are available, precluding the use of biological and toxicokinetic data comparing this chemical with the candidate analogues as a means of choosing the most appropriate analogue. Structural similarity scores do not provide a meaningful or objective way to differentiate between analogues and thus were not used to select analogues. Thus, in addition to the overall WOE, availability of toxicity values, duration of key studies, and sensitivity of critical effects was also taken into consideration when choosing the most appropriate analogue, as described below.

Subchronic oral provisional reference doses (p-RfDs) derived by U.S. EPA are available for 3-nitroaniline and 4-nitroaniline (U.S. EPA, 2009a, b); formal subchronic oral toxicity values were not available for any of the other candidate analogues. However, the PODs from the chronic oral toxicity values developed for 1,3-dinitrobenzene [Reddy et al. (1996) as cited in U.S. EPA (1997)] and 2,4,6-trinitrotoluene [U.S. DOD (1983) as cited in U.S. EPA (2002a); Levine et al. (1990) as cited in ATSDR (1995b)] were also considered for development of a screening subchronic p-RfD because they were based on subchronic study designs for the principal study. 4-Nitroaniline is selected as the appropriate analogue for deriving a screening subchronic p-RfD for 3,5-dinitroaniline based on the following factors:

1) Although the POD (0.40 mg/kg-day, based on increased spleen weight) used by IRIS to derive a chronic RfD for 1,3-dinitrobenzene comes from a subchronic study [Cody et al. (1981) as cited in U.S. EPA (2005b)], methemoglobin changes were not evaluated in the Cody et al. (1981) [as cited in U.S. EPA (2005b)] study. As discussed above, increased methemoglobin was chosen as the critical effect for 4-nitroanline and 1,3,5-trinitrobenzene, and 2,4,6-trinitrotoluene and 3-nitroaniline were both observed to increase methemoglobin in dogs and rats, respectively.
2) On initial review, 1,3-dinitrobenzene has the lowest POD (0.4 mg/kg-day, used by IRIS to derive a chronic RfD) based on increased spleen weight from a NOAEL in a 16-week rat study that exposed animals via drinking water [Cody et al. (1981) as cited in U.S. EPA (2005b)]. Similar in magnitude is the POD used by IRIS to derive a chronic RfD for 2,4,6-trinitrotoluene (0.5 mg/kg-day) based on hepatocyte swelling from a LOAEL in a 25-week dog study that exposed animals via gelatin capsules [U.S. DOD (1983) as cited in U.S. EPA (2002a); Levine et al. (1990) as cited in ATSDR (1995b)]. The differences in species and routes of exposure make it challenging to do a direct comparison with other analogues and may contribute to the differences in observed critical effects. Methemoglobin changes were not evaluated for 1,3-dinitrobenzene in Cody et al. (1981) [as cited in U.S. EPA (2005b)], but were evaluated and observed at higher doses for TNT [U.S. DOD (1983) as cited in U.S. EPA (2002a); Levine et al. (1990) as cited in ATSDR (1995b)].
3) The POD used to derive the subchronic p-RfD for 4-nitroaniline (0.95 mg/kg-day, based on increased methemoglobin) was lower than the POD used to derive the 3-nitroaniline subchronic p-RfD (15 mg/kg-day, based on decreased RBC counts and hemoglobin).
4) The principal study upon which the subchronic p-RfD for 4-nitroaniline is based was of a longer duration (90 days) than the study upon which the subchronic p-RfD for 3-nitroaniline was based (28 days). Although the duration of the 1,3-dinitrobenzene study was 16 weeks and for 2,4,5-trinitrotoluene 25 weeks, there are also chronic toxicity data on methemoglobin effects (from a 2-year oral study) available for multiple time points following 4-nitroaniline exposure. The larger evidence base for a longer time frame, in addition to having inhalation toxicology data for the same analogue, strengthens the confidence in the body of available toxicology effects for 4-nitroaniline. The overall database for methemoglobinemia following 4-nitroaniline exposure is more robust, containing both subchronic and chronic (2-year bioassay) oral exposure data as well as inhalation data.

Chronic p-RfDs derived by U.S. EPA are available for 4-nitroaniline (U.S. EPA, 2009b), 1,3,5-trinitrobenzene (U.S. EPA, 1997), 1,3-dinitrobenzene (U.S. EPA, 2005b), and TNT (U.S. EPA, 2002a). Similar to the screening subchronic p-RfD, 4-nitroaniline is selected as the appropriate analogue for deriving a screening chronic p-RfD for 3,5-dinitroaniline based on the following factors:

1) The POD for the 4-nitroaniline chronic p-RfD (0.37 mg/kg-day) was significantly lower (>sevenfold) than the POD for 1,3,5-trinitrobenzene (2.68 mg/kg-day), and also slightly lower than the PODs used to derive the other screening chronic p-RfDs (0.40 and 0.5 mg/kg-day for 1,3-dinitrobenzene and TNT, respectively), making the 4-nitroaniline value the most health conservative value.
2) Unlike the other candidate analogues, hepatic effects (hepatocyte swelling) in dogs were the most sensitive endpoints following oral TNT exposure, and increased methemoglobin levels and hemosiderin deposition in the liver were observed at higher doses (8 and 32 mg/kg-day), which adds uncertainty given that increased methemoglobin was chosen as the critical effect for 4-nitroanline and 1,3,5-trinitrobenzene. Because the TNT principal study used a different species (dogs) and exposure route (gelatin capsules), this may partially explain the differences in sensitive endpoints.
3) The principal study upon which the chronic p-RfD for 4-nitroaniline is based was a chronic 2-year rat study, while studies used as the basis for the chronic p-RfDs for 1,3-dinitrobenzene and TNT were subchronic in duration (16-week rat study and 25-week dog study, respectively).

Subchronic and chronic p-RfCs derived by U.S. EPA are available only for 4-nitroaniline; inhalation toxicity values were not available for any of the other candidate analogues. As stated above, 4-nitroaniline is an appropriate structural and metabolic analogue for 3,5-dinitroaniline. As with the toxic effects observed following oral exposure, inhalation exposure to 4-nitroaniline also results in increased methemoglobin levels in rats. Thus, based on the WOE approach and availability of p-RfCs, 4-nitroaniline is selected as the model analogue for deriving screening subchronic and chronic p-RfCs for 3,5-dinitroaniline.

## ORAL NONCANCER REFERENCE VALUES

### Derivation of a Screening Subchronic Provisional Reference Dose

Based on the overall WOE approach presented in this PPRTV assessment, 4-nitroaniline is selected as the analogue for 3,5-dinitroaniline for deriving a screening subchronic p-RfD. The principal study used to derive the subchronic p-RfD for 4-nitroaniline was a 90-day rat study [Monsanto (1981) and Houser et al. (1983) as cited in U.S. EPA (2009b)]. The PPRTV assessment (U.S. EPA, 2009b) described the study as follows:

Monsanto Co. (1981b) and Houser et al. (1983) reported a 90-day gavage study in which groups of 20 male and 20 female Sprague-Dawley rats were administered daily doses of 0, 3, 10, or 30 mg/kg-day of 4-nitroaniline (purity 99.85%) in corn oil. Animals were observed daily for mortality and clinical signs of toxicity. Body weights and food consumption were determined weekly. After 45 and again after 90 days of treatment, blood and urine samples were collected from 10 rats/sex/group for hematology, clinical chemistry, and urinalysis. At the end of the treatment period, all surviving animals were sacrificed and necropsied; selected organs were weighed, and histopathological examination was performed on comprehensive tissues.

No treatment-related mortalities occurred, with only one mortality in the control group (female) during the course of the study (Monsanto Co., 1981b; Houser et al., 1983). Body weight and food consumption were comparable to controls in all 4-nitroaniline treatment groups. Ear paleness (indicative of anemia) was observed in males treated with 30 mg/kg-day during treatment Week 2 (2/20 rats) and Week 4 (20/20) and in females treated with 30 mg/kg-day during treatment Weeks 2 (2/20 rats), Week 4 (20/20), and Week 6 (20/20). Ear paleness was not observed in any rats on other weeks during the treatment period. No other significant clinical signs of toxicity were observed. Clinical chemistry parameters in treatment groups were comparable to controls. Treatment-related effects on hematology parameters and histopathological findings were consistent with the effects of increased blood concentrations of methemoglobin; specifically, accelerated red blood cell (RBC) destruction (hemolytic anemia), and compensatory erythropoiesis to maintain erythrocyte mass. Methemoglobin concentration and reticulocyte count were significantly increased in all 4-nitroaniline treatment groups after 90 days of treatment (see Table 2). Other significant hematology findings in both sexes included decreased erythrocyte count, Hct, and blood hemoglobin concentration in males and females treated with ≥10 mg/kg-day, and decreased mean cell hemoglobin (MCH) and mean cell volume (MCV) in the 30 mg/kg-day group. Comprehensive histopathologic examination of the controls and 30 mg/kg-day rats identified the spleen as the only organ with treatment-related lesions; therefore, the spleens of all rats were examined microscopically. Dose-related increases in splenic congestion, hemosiderosis, and extramedullary hematopoiesis were observed in all treated groups (see Table 3). The LOAEL for 90-day oral exposure has been identified as a daily average dose of 3 mg/kg-day for the development of methemoglobinemia and associated hematological and splenic changes; a NOAEL is not established.

The critical effect in this study was increased methemoglobin in female rats. A BMDL_1SD_ of 0.95 mg/kg-day was derived from benchmark dose (BMD) modeling of the methemoglobin data in female rats and used as the POD for 4-nitroaniline (U.S. EPA, 2009b). This value is selected as the POD to derive the screening subchronic p-RfD for 3,5-dinitroaniline. The POD was not adjusted for molecular weight differences in the derivation of the 3,5-dinitroaniline provisional toxicity value because the molecular weight difference between the two compounds is less than twofold (Wang et al., 2012).

The BMDL_1SD_ of 0.95 mg/kg-day is converted to a human equivalent dose (HED) according to current U.S. EPA (2011c) guidance. In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c), the Agency endorses a hierarchy of approaches to derive human equivalent oral exposures from data from laboratory animal species, with the preferred approach being physiologically based toxicokinetic modeling. Other approaches may include using some chemical-specific information, without a complete physiologically based toxicokinetic model. In the absence of chemical-specific models or data to inform the derivation of human equivalent oral exposures, U.S. EPA endorses body-weight scaling to the 3/4 power (i.e., BW^3/4^) as a default to extrapolate toxicologically equivalent doses of orally administered agents from all laboratory animals to humans for the purpose of deriving an RfD under certain exposure conditions. More specifically, the use of BW^3/4^ scaling for deriving an RfD is recommended when the observed effects are associated with the parent compound or a stable metabolite but not for portal-of-entry effects or developmental endpoints.

A validated human physiologically based pharmacokinetic model for 4-nitroaniline is not available for use in extrapolating doses from animals to humans (U.S. EPA, 2009b). The selected POD is based on increased methemoglobin, which is not a portal-of-entry or developmental effect. Therefore, scaling by BW^3/4^ is relevant for deriving HEDs for this effect.

Following U.S. EPA (2011c) guidance, the POD for increased methemoglobin in female rats is converted to an HED by applying a dosimetric adjustment factor (DAF) derived as follows:

DAF = ( BW_a_ 1 / 4 ÷ BW_h_ 1 / 4 )

where:

- DAF = dosimetric adjustment factor
- BW_a_ = animal body weight
- BW_h_ = human body weight

Using a reference BW_a_ of 0.204 kg for female Sprague Dawley rats and a reference BW_h_ of 70 kg for humans (U.S. EPA, 1988), the resulting DAF is 0.23. Applying this DAF to the BMDL_1SD_ of 0.95 mg/kg-day yields a POD (HED) as follows:

POD ( HED ) = BMDL_1 SD_ ( mg / kg-day ) × DAF = 0.95 mg / kg-day × 0.23 = 0.22 mg / kg-day

The U.S. EPA (2009b) subchronic p-RfD for 4-nitroaniline was derived using a composite uncertainty factor (UF_C_) of 100, reflecting 10-fold uncertainty factors for both interspecies extrapolation and intraspecies variability (interspecies uncertainty factor [UF_A_] and intraspecies uncertainty factor [UF_H_]). An uncertainty factor for database uncertainties (UF_D_) was not applied due to the availability of well-designed subchronic and chronic studies in two species, as well as developmental toxicity studies in two species and a multigeneration reproductive toxicity study (U.S. EPA, 2009b). Wang et al. (2012) indicated that the uncertainty factors typically applied in deriving a toxicity value for the chemical of concern are the same as those applied to the analogue unless additional information is available. In deriving the screening subchronic p-RfD for 3,5-dinitroaniline, a UF_A_ of 3 is applied to account for uncertainty associated with extrapolating from animals to humans when cross-species dosimetric adjustment (HED calculation) is performed. In addition, a UF_D_ of 10 is used for database uncertainties to account for the absence of any toxicity information for 3,5-dinitroaniline. A UF_H_ of 10 is applied to account for human-to-human variability. Thus, the screening subchronic p-RfD for 3,5-dinitroaniline was derived using a UF_C_ of 300 reflecting a UF_A_ of 3, UF_H_ of 10, and UF_D_ of 10.

Screening Subchronic p-RfD = Analogue POD ( HED ) ÷ UF_C_ = 0.22 mg / kg-day ÷ 300 = 7 × 10^− 4^ mg / kg-day

Table A-7 summarizes the uncertainty factors for the screening subchronic p-RfD for 3,5-dinitroaniline.

Table A-7 Uncertainty Factors for the Screening Subchronic p-RfD for 3,5-Dinitroaniline (CASRN 618-87-1)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rats and humans following 3,5-dinitroanline exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c). Dosimetric adjustment calculations were performed on the POD for the selected analogue, 4-nitroaniline.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for the absence of toxicity data for 3,5-dinitroaniline.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 3,5-dinitroaniline in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the analogue POD is a BMDL_1SD_.
UF_S_ | 1 | A UF_S_ of 1 is applied because a subchronic study was selected as the principal study for the subchronic assessment.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMDL_1SD_ = benchmark dose lower confidence limit, one standard deviation; DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor(s); UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of a Screening Chronic Provisional Reference Dose

Based on the overall WOE approach presented in this PPRTV assessment, 4-nitroaniline is selected as the analogue for 3,5-dinitroaniline for deriving a screening chronic p-RfD. The principal study used to derive the chronic p-RfD for 4-nitroaniline was a 2-year rat study [Nair et al. (1990) as cited in U.S. EPA (2009b)]. U.S. EPA (2009b) described the study as follows:

The effects of chronic oral exposure to 4-nitroaniline have been investigated in a 2-year gavage study in rats (Nair et al., 1990). Nair et al. (1990) treated groups of 60 male and 60 female Sprague-Dawley rats by daily gavage with 4-nitroaniline (purity 99.9%) in corn oil at doses of 0, 0.25, 1.5, or 9.0 mg/kg daily for 2 years. Rats were observed for mortality and clinical signs of toxicity twice daily, and were given detailed physical examinations weekly. Ophthalmoscopic examinations were conducted on all rats prior to treatment, and after 3, 12, and 24 months of treatment. Body weights and food consumption were recorded weekly for the first 14 weeks and biweekly thereafter. Hematology (MetHgb, Hgb, Hct, RBC count, reticulocyte count, WBC count with differential), serum chemistry (complete list not reported, but included serum sodium and potassium), and urinalysis (gross appearance, specific pH, protein, glucose, ketones, bilirubin, occult blood, and urobilinogen and microscopic examination of sediment) were evaluated after 6, 10, 12, 18, and 24 months of treatment in randomly selected animals (10/sex/group); blood methemoglobin levels were evaluated at 6, 10, 12, 18, and 24 months. Complete necropsies were conducted on all animals. Organ weights of adrenals, brain, ovaries, testes, kidneys, liver, heart, and spleen were recorded for rats surviving at 2 years. Tissue masses, gross lesions, and tissue samples (35 tissues) were examined microscopically in all control and high-dose animals. In addition, all gross lesions and tissue masses, as well as the spleen and liver, were examined microscopically in low- and mid-dose animals.

Treatment resulted in slightly increased mortality in males treated with 9.0 mg/kg-day (44 deaths), relative to control (37 deaths) (Nair et al., 1990). Although the increase was not statistically significant by pairwise comparison, Life Table analysis showed a statistically significant positive trend for the males. Weekly mean body weights for 4-nitroaniline-treated males were similar to controls throughout the study. For females, weekly mean body weights were similar to controls for the 0.25 and 1.50 mg/kg-day groups, but tended to be higher than control values in the 9.0 mg/kg-day group, with differences reaching statistical significance at various times throughout the study (data not reported). Increased food intake occurred sporadically throughout the study in rats of both sexes treated with 1.5 or 9.0 mg/kg-day (data not reported). There were no treatment-related effects on clinical observations, ophthalmoscopic examinations, clinical chemistry, or urinalysis. Significant changes in hematological parameters attributed to 4-nitroaniline after 12 and 24 months of exposure are summarized in Table 11 (data from other time points not reported). Methemoglobin levels were increased in the 1.5 and 9.0 mg/kg-day groups at both time points in a dose-related manner in both sexes. In the high-dose groups, the increases in methemoglobin were large (6–8-fold over control levels) and methemoglobin levels exceeded 2%. Small decreases in hemoglobin and red blood cell count were also seen in the high-dose groups.

In male rats, administration of 4-nitroaniline produced a dose-related increase in absolute and relative spleen weights in the 1.5 and 9.0 g/kg-day groups and increased relative liver weights in the 9.0 mg/kg-day group (see Table 12). Treatment did not affect absolute or relative organ weights in female rats. Microscopic examination revealed increased accumulations of brown pigment (probably hemosiderin) in the Kupffer cells (sinusoidal macrophages) of the liver and reticuloendothelial cells of the spleen of treated rats (see Table 12). Statistical analysis of data was not performed by the study authors. Fisher’s exact tests performed for this review showed that the increases were statistically significant in the liver in the high-dose groups of both sexes and in the 1.5 mg/kg-day group in males. The incidence of hemosiderosis in the spleen was significantly increased in males of the 1.5 and 9.0 mg/kg-day groups. Due to the high incidence of splenic hemosiderosis in control females, there was no increase in overall incidence with treatment. However, the severity of splenic hemosiderosis increased with dose in both sexes. The Jonckheere-Terpstra test performed for this review showed that the increase in severity was statistically significant at ≥0.25 mg/kg-day in the female rats. The same pattern was seen in the male rats, although the increase in severity in males was not statistically significant at doses lower than 9.0 mg/kg-day. Based on increased methemoglobin in both male and female rats, and increases in spleen weights and hemosiderosis in the liver and spleen in male rats, the NOAEL and LOAEL in this study were 0.25 mg/kg-day and 1.5 mg/kg-day, respectively.

The critical effect for this study was methemoglobinemia in male rats (U.S. EPA, 1997). U.S. EPA (2009b) used a BMDL_1SD_ of 0.37 mg/kg-day, obtained by modeling the methemoglobinemia data in male rats, as the POD. As with the derivation of the screening subchronic p-RfD, the POD was not adjusted for molecular weight differences between 3,5-dinitroaniline and the analogue because the difference is less than twofold (Wang et al., 2012).

The BMDL_1SD_ of 0.37 mg/kg-day is converted to an HED using a DAF by using a reference BW_a_ of 0.523 kg for male Sprague Dawley rats under chronic study conditions and a reference BW_h_ of 70 kg for humans (U.S. EPA, 1988), the resulting DAF is 0.29 using the same methods described earlier when deriving the screening subchronic p-RfD. Applying this DAF to the 10% benchmark dose lower confidence limit (BMDL_10_) of 0.37 mg/kg-day yields a POD (HED) as follows:

POD ( HED ) = BMDL_1 SD_ ( mg / kg-day ) × DAF = 0.37 mg / kg-day × 0.29 = 0.11 mg / kg-day

The U.S. EPA (2009b) chronic p-RfD for 4-nitroaniline was derived using a UF_C_ of 100, reflecting 10-fold uncertainty factors for both UF_A_ and UF_H_ variability. An uncertainty factor for database uncertainties (UF_D_) is not applied because of the availability of well-designed subchronic and chronic studies in two species, as well as developmental studies in two species and a multigeneration reproduction study (U.S. EPA, 2009b). In deriving the screening chronic p-RfD for 3,5-dinitroaniline, a UF_A_ of 3 is used to account for uncertainty associated with extrapolating from animals to humans when cross-species dosimetric adjustment (HED calculation) is performed. A UF_H_ of 10 is applied to account for human-to-human variability. In addition, a UF_D_ of 10 is used for database uncertainties to account for the absence of any toxicity information for 3,5-dinitroaniline. Thus, the screening chronic p-RfD for 3,5-dinitroaniline is derived using a UF_C_ of 300 reflecting a UF_A_ of 3, UF_H_ of 10, and UF_D_ of 10.

Screening Chronic p-RfD = Analogue POD ( HED ) ÷ UF_C_ = 0.11 mg / kg-day ÷ 300 = 4 × 10^− 4^ mg / kg-day

Table A-8 summarizes the uncertainty factors for the screening chronic p-RfD for 3,5-dinitroaniline.

Table A-8 Uncertainty Factors for the Screening Chronic p-RfD for 3,5-Dinitroaniline (CASRN 618-87-1)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rats and humans following 3,5-dinitroanline exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c). Dosimetric adjustment calculations were performed on the POD for the selected analogue, 4-nitroaniline.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for the absence of toxicity data for 3,5-dinitroaniline.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 3,5-dinitroaniline in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the analogue POD is a BMDL_1SD_.
UF_S_ | 1 | A UF_S_ of 1 is applied because a chronic study was selected as the principal study for the chronic assessment.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMDL_1SD_ = benchmark dose lower confidence limit, one standard deviation; DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor(s); UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

## INHALATION NONCANCER REFERENCE VALUES

### Derivation of a Screening Subchronic Provisional Reference Concentration

Based on the overall WOE approach presented in this PPRTV assessment, 4-nitroaniline is selected as the analogue for 3,5-dinitroaniline to derive a screening subchronic p-RfC. Subchronic and chronic p-RfCs derived by U.S. EPA are available only for 4-nitroaniline; inhalation toxicity values were not available for any of the other candidate analogues. Note that there are uncertainties in the selection of 4-nitroaniline as the analogue given the lack of other analogues with published inhalation toxicity values. Additional uncertainty is introduced by the lack of toxicokinetic data to inform about route-specific toxicokinetic differences between the target and analogue chemical. The principal study used for the U.S. EPA (2009b) subchronic p-RfC for 4-nitroaniline was a 4-week rat study [Nair et al. (1986) as cited in U.S. EPA (2009b)]. Like oral exposure, inhalation exposure to 4-nitroaniline also results in increased methemoglobin in rats. U.S. EPA (2009b) described the study as follows:

The effects of inhalation exposure of rats to 4-nitroaniline for 4 weeks was studied by Nair et al., (1986). Groups of 10 male (204–243 g) and 10 female (204–243 g) Sprague-Dawley rats were exposed (whole body exposure) to an aerosol of 4-nitroaniline 6 hours/day, 5 days/week, for 4 weeks. 4-Nitroaniline was dissolved in isopropyl alcohol and the solution fed into a spray atomizer. Mean measured exposure concentrations for 4-nitroaniline were 0 (1500 ppm solvent only), 10, 32, and 80 mg/m^3^. Particle size mass median aerodynamic diameters and geometric standard deviations (MMAD ± GSD) were 0.80 ± 5.42, 1.37 ± 4.04 and 0.78 ± 6.42 μm for the 10, 32, and 80 mg/m^3^ exposures, respectively. Endpoints monitored throughout the study include mortality, clinical signs, and body weights. A comprehensive ophthalmoscopic examination was performed on all rats before the study began and prior to termination of the study. Blood was drawn from all animals before sacrifice for hematologic and clinical chemistry determinations. At the end of the study, all rats underwent gross necropsy and the major organs were weighed. Microscopic examinations of all major organs and tissues (including nasal turbinates, trachea, and lungs) of all control and high-exposure rats, and of spleens of all rats, were performed.

No mortality or compound-related clinical signs of toxicity were observed during the study, and body weights were not different from controls (data not reported) (Nair et al., 1986). Results from the ophthalmoscopic examinations showed no treatment-related changes. Hematologic changes attributed to exposure to 4-nitroaniline were: a concentration-related increase in blood methemoglobin (MetHb) levels in male and female rats that was statistically significant at ≥32 mg/m^3^; an increased incidence of morphological changes in the red blood cells (polychromasia in both sexes and anisocytosis in females) at ≥32 mg/m^3^ (incidence data and statistical significance not reported); and significantly increased WBC counts in males at 80 mg/m^3^ (see Table 13). Data on RBC counts were not reported. These changes in hematological parameters are consistent with 4-nitroaniline-induced methemoglobinemia and compensatory hematopoiesis. No treatment-related clinical chemistry findings or gross pathological changes were observed. Increased relative and absolute spleen weights were observed in males and females in all 4-nitroaniline groups (see Table 14). Hemosiderosis and extramedullary hematopoiesis in the spleen were observed in all groups with comparable frequency; however, the severity of the changes was concentration-related (see Table 14). Livers of the high-exposure females had a qualitatively higher degree of extramedullary hematopoiesis relative to the controls (data not reported). No compound-related histopathological changes were observed in other tissues. A LOAEL of 10 mg/m^3^ was identified for increased spleen weights and severity of splenic hemosiderosis and extramedullary hematopoiesis in males and females. The corresponding human equivalent concentration (HEC) is 4.2 mg/m^3^ for the systemic toxicity. A NOAEL was not identified.

The critical effect for this study was methemoglobinemia in male rats (U.S. EPA, 1997). U.S. EPA (2009b) used a BMCL_1SD_ (HEC) of 1.7 mg/m^3^, obtained by modeling the methemoglobinemia data in male rats, as the POD. As with the derivation of the oral toxicity values, the POD was not adjusted for molecular weight differences between 3,5-dinitroaniline and the analogue because the difference is less than twofold (Wang et al., 2012). A UF_C_ of 100, reflecting a 10-fold factor for UF_H_ and 3-fold factors for both UF_A_ and UF_D_, was applied to the POD to obtain the subchronic p-RfC for 4-nitroaniline (U.S. EPA, 2009b). In deriving the screening subchronic p-RfC for 3,5-dinitroaniline, a full 10-fold UF_D_ is used to account for the absence of any toxicity information for 3,5-dinitroaniline. Thus, the screening subchronic p-RfC for 3,5-dinitroaniline is derived using a UF_C_ of 300 reflecting a UF_A_ of 3, UF_H_ of 10, and UF_D_ of 10.

Screening Subchronic p-RfC = Analogue POD ( HEC ) ÷ UF_C_ = 1.7 mg / m^3^ ÷ 300 = 6 × 10^− 3^ mg / m^3^

Table A-9 summarizes the uncertainty factors for the screening subchronic p-RfC for 3,5-dinitroaniline.

Table A-9 Uncertainty Factors for the Screening Subchronic p-RfC for 3,5-Dinitroaniline (CASRN 618-87-1)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans when cross-species dosimetric adjustment (HEC calculation) is performed.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for the absence of toxicity data for 3,5-dinitroaniline.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 3,5-dinitroaniline in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the analogue POD is a BMCL_1SD_.
UF_S_ | 1 | A UF_S_ of 1 for exposure duration is applied. As noted by U.S. EPA (2009b) in describing the application of a UF_S_ for the 4-nitroaniline analogue compound, “based on results of subchronic oral toxicity studies, maximum blood methemoglobin levels appear to be reached within 2–7 wk of exposure to 4-nitroaniline. These levels decline and reach a plateau within 3 mo. It is unlikely that the duration-related plateau varies with route of exposure.”
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMCL_1SD_ = benchmark concentration lower confidence limit, one standard deviation; HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; UF = uncertainty factor(s); UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of a Screening Chronic Provisional Reference Concentration

Based on the overall analogue approach presented in this PPRTV assessment, 4-nitroaniline is selected as the analogue for 3,5-dinitroaniline for deriving a screening chronic p-RfC. To derive the chronic p-RfC for 4-nitroaniline, U.S. EPA (2009b) used the same study [Nair et al. (1986) as cited in U.S. EPA (2009b)] and POD (BMCL_1SD_ [HEC] of 1.7 mg/m^3^) as was used to derive the screening subchronic p-RfC. A UF_C_ of 300, reflecting a 10-fold factor for UF_H_ and 3-fold factors for UF_A_, UF_D_, and UF_S_, was applied to the POD to obtain the chronic p-RfC for 4-nitroaniline. Although a 4-week study would not typically be used as the basis for a chronic p-RfC, U.S. EPA (2009b) argued that methemoglobin levels are not significantly affected by exposure duration. The use of a threefold UF_S_ in deriving the chronic value from the 4-week study was to account for potential effects of exposure duration on other health outcomes. As stated in U.S. EPA (2009b), methemoglobin blood levels plateau after several months of exposure, and there is evidence in the nitroarene literature that methemoglobinemia and the constellation of sequelae, including splenic and hepatic effects, do not seem to significantly increase in incidence and/or severity with chronic exposures. In summary, when looking across the health effects in the previous examples, hematological effects seem to reach a plateau suggesting that an increase in duration of exposure will lead to some increases in incidence and/or severity but not to the extent to warrant the application of a 10-fold UF_S_. A threefold UF_S_ is applied to cover any remaining uncertainty.

In deriving the screening chronic p-RfC for 3,5-dinitroaniline, a full 10-fold UF_D_ is used to account for the absence of any toxicity information for 3,5-dinitroaniline. Thus, the screening chronic p-RfC for 3,5-dinitroaniline is derived using a UF_C_ of 1,000 reflecting a UF_A_ of 3, UF_H_ of 10, UF_D_ of 10, and UF_S_ of 3.

Screening Chronic p-RfC = Analogue POD ( HEC ) ÷ UF_C_ = 1.7 mg / m^3^ ÷ 1,000 = 2 × 10^− 3^ mg / m^3^

Table A-10 summarizes the uncertainty factors for the screening chronic p-RfC for 3,5-dinitroaniline.

Table A-10 Uncertainty Factors for the Screening Chronic p-RfC for 3,5-Dinitroaniline (CASRN 618-87-1)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans when cross-species dosimetric adjustment (HEC calculation) is performed.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for the absence of toxicity data for 3,5-dinitroaniline.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 3,5-dinitroaniline in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a BMCL_1SD_.
UF_S_ | 3 | A UF_S_ of 3 (10^0.5^) is applied for a less than chronic exposure duration. As noted by U.S. EPA (2009b) in describing the application of a UF_S_ for the 4-nitroaniline analogue compound, “based on results of subchronic oral toxicity studies, maximum blood methemoglobin levels appear to be reached within 2–7 wk of exposure. These values then decline and reach a plateau within 3 mo. It is unlikely that the duration-related plateau varies with route of exposure. However, due to lack of chronic inhalation data, it is not known if lifetime inhalation exposure to 4-nitroaniline produces adverse effects in other organs, such as the respiratory tract.”
UF_C_ | 1,000 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMCL_1SD_ = benchmark concentration lower confidence limit, one standard deviation; HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; UF = uncertainty factor(s); UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.