# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGERS

- Lucina E. Lizarraga, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Jeffry L. Dean II, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## CONTRIBUTORS

- Chelsea A. Weitekamp, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC
- James A. Weaver, PhD, DABT
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## SCIENTIFIC TECHNICAL LEAD

- Lucina E. Lizarraga, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Daniel D. Petersen, MS, PhD, DABT, ATS, ERT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Suryanarayana V. Vulimiri, BVSc, PhD, DABT
  Center for Public Health and Environmental Assessment, Washington, DC

## PRIMARY EXTERNAL REVIEWERS

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.