# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF ORAL REFERENCE DOSES

The database of repeat-dose oral studies for dibenzothiophene is limited to a non-peer-reviewed, 28-day study in Japanese with only tables and figures in English (JECDB, 2011) and a peer-reviewed, 165-day study from 1942 that relied on historical laboratory control groups instead of a concurrent control (Thomas et al., 1942). Due to the shortcomings of these studies, reference doses (RfDs) cannot be confidently derived here. However, the studies provide sufficient data to develop a screening subchronic provisional reference dose (p-RfD) value (see Appendix A).

## 3.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

No subchronic or chronic provisional reference concentration (p-RfC) can be derived because no inhalation studies on exposure to dibenzothiophene were identified.

The feasibility of using an analogue approach was attempted for the derivation of screening-level p-RfC values via read-across but no candidate analogues with inhalation toxicity values were identified (see Appendix A).

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

Table 5 presents a summary of the noncancer provisional references values.

Table 5 Summary of Noncancer Risk Estimates for Dibenzothiophene (CASRN 132-65-0)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) (see Appendix A) | Rat/F | Increased hepatocyte hypertrophy | 3 × 10^−3^ | BMDL_10_ | 1.04 | 300 | JECDB (2011)
Chronic p-RfD (mg/kg-d) | NDr
Subchronic p-RfC (mg/m^3^) | NDr
Chronic p-RfC (mg/m^3^) | NDr

BMD = benchmark dose; BMDL = 95% benchmark dose lower confidence limit on the BMD (subscripts denote BMR: i.e., 10 = dose associated with 10% extra risk); HEC = human equivalent concentration; HED = human equivalent dose; NDr = not determined; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UFC = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

No human or animal data were located on the carcinogenicity of dibenzothiophene by oral or inhalation exposure. One available injection study observed dysplastic lesions in the intestines of rats treated for 10 weeks, suggesting that dibenzothiophene may have some carcinogenic potential (Silva et al., 2015). Genotoxicity studies were largely negative, including multiple Ames tests for mutation in bacteria and assays for mutation and CAs in mammalian cells (JECDB, 2010a, b; Madill et al., 1999; Rasmussen et al., 1991; Mcfall et al., 1984; Pelroy et al., 1983; Dickson and Adams, 1980). Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is “Inadequate Information to Assess Carcinogenic Potential” of dibenzothiophene by oral or inhalation exposure (see Table 6).

Table 6 Cancer WOE Descriptor for Dibenzothiophene (CASRN 132-65-0)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | No human carcinogenicity data are available.
“Likely to Be Carcinogenic to Humans” | NS | NA | No adequate animal cancer bioassays or human cancer data are available.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | No adequate animal cancer bioassays or human cancer data are available.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | Selected due to the lack of adequate data on carcinogenicity. One injection study provided limited evidence of carcinogenic potential.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available.

NA = not applicable; NS = not selected; WOE = weight-of-evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

The absence of suitable data precludes the development of cancer risk estimates for dibenzothiophene (see Table 7).

Table 7 Summary of Cancer Risk Estimates for Dibenzothiophene (CASRN 132-65-0)

Toxicity Type | Species/Sex | Tumor Type | Cancer Value | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.