# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

Tables 3A and 3B provide overviews of the relevant noncancer and cancer evidence bases, respectively, for dibenzothiophene and include all repeated-dose short-term, subchronic, and chronic studies, as well as reproductive and developmental toxicity studies identified from the literature search. Principal studies used in the PPRTV assessment for derivation of provisional toxicity values are identified in bold. The phrase “statistical significance” and term “significant,” used throughout the document, indicate a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for Dibenzothiophene (CASRN 132-65-0)

Category^a^ | Number of Male/Female, Strain, Species, Study Type, Study Duration, Reported Doses | Dosimetry^b^ | Critical Effects | NOAEL^b^ | LOAEL^b^ | Reference (comments) | Notes^c^
Human
1. Oral (mg/kg-day)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-day)
Short-term | 6–12 M/6–12 F, Sprague Dawley, rat, unspecified oral, 28 d; Reported doses: 0, 3, 10, 30 mg/kg-d | 0, 3, 10, 30 | Increased relative liver weight in both males and females and reduced motor activity and increased prothrombin time in males at ≥10 mg/kg-d. Other effects occurring mostly at the highest dose (30 mg/kg-d): hepatocyte hypertrophy in males and females and changes in serum markers of liver function in males (reduced albumin protein fraction and A/G ratio); increased relative kidney weights and kidney lesions in males; increased APTT in males. | 3 | 10 | JECDB (2011) | PS, NPR
Subchronic to Chronic | Male (number not specified), albino, rat, diet, 165 d; Reported dietary concentrations: 0 (historical), 0.025, 0.05, 0.10% | 0 (historical), 13, 27, 63 | Increased liver weight compared with laboratory historical controls; histopathological changes in liver. | NDr | NDr | Thomas et al. (1942) (The design and reporting limitations [including the lack of a concurrent control and information on the number of test animals] prevent the determination of effect levels for this study.) | PR
2. Inhalation (mg/m^3^)
ND

a Duration categories are defined as follows: acute = exposure for ≤24 hours; short term = repeated exposure for >24 hours to ≤30 days; long-term (subchronic) = repeated exposure for >30 days or ≤10% life span for humans (>30 days up to approximately 90 days in typically used laboratory animal species); and chronic = repeated exposure for >10% life span for humans (>~90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002).

b Dosimetry: doses are presented as ADDs (mg/kg-day) for oral noncancer effects and as HECs (in mg/m^3^) for inhalation noncancer effects.

c Notes: NPR = not peer reviewed; PR = peer reviewed; PS = principal study.

ADD = adjusted daily dose; A/G = albumin/globulin; APTT = activated partial thromboplastin time; F = female(s); HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = no data; NDr = not determined; NOAEL = no-observed-adverse-effect level.

Table 3B Summary of Potentially Relevant Cancer Data for Dibenzothiophene (CASRN 132-65-0)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Duration | Dosimetry | Critical Effects | Reference (comments) | Notes
Human
1. Oral (mg/kg-day)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-day)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

## 2.1 HUMAN STUDIES

### 2.1.1 Oral Exposures

No studies were identified.

### 2.1.2 Inhalation Exposures

No studies were identified.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures

The effects of oral exposure to dibenzothiophene in animals have been evaluated in short-term (JECDB, 2011) and chronic (Thomas et al., 1942) studies in rats.

#### Short-Term Studies

##### JECDB (2011)

In an OECD Test Guideline (TG) 407 study from the Japanese literature (JECDB, 2011), groups of 12, 6, 6, and 12 Crl:CD(SD) rats/sex received dibenzothiophene at doses of 0, 3, 10, or 30 mg/kg-day, respectively, by oral administration (additional details not available in English from the existing Japanese language report) for 28 days. At the end of exposure, six rats/sex/group were sacrificed; six rats/sex in the control and high-dose groups were followed for an additional 14 days untreated (recovery) prior to sacrifice. The animals were observed for clinical signs of toxicity, and body weight and food intake were measured once each week. Detailed clinical observations of the animals in cages, during handling, and in open field were performed weekly. During exposure week 4 and recovery week 2, the animals were subjected to functional observational battery (FOB), assessing reactivity (visual, touch, auditory, pain, proprioceptive), righting reflex, grip strength, and motor activity. Blood and urine were collected at the end of exposure and at the end of the recovery period. Hematology parameters included erythrocytes (red blood cells [RBCs] and reticulocyte counts, hemoglobin, hematocrit, mean corpuscular volume [MCV], mean corpuscular hemoglobin [MCH], mean corpuscular hemoglobin concentration [MCHC]), platelet counts, prothrombin time [PT], activated partial thromboplastin time [APTT], and white blood cells [WBCs; total and differential counts]). Serum chemistry was evaluated including total protein, albumin, globulins, albumin/globulin (A/G) ratio, aspartate aminotransferase (AST), alanine aminotransferase (ALT), alkaline phosphatase (ALP), γ-glutamyl transferase (GGT), total bilirubin, glucose, total cholesterol, triglycerides, blood urea nitrogen (BUN), creatinine, and electrolytes. Urinalysis parameters included pH, protein, glucose, ketone bodies, urobilinogen, bilirubin, occult blood, color, volume, and specific gravity. All animals received gross necropsy. The following organs were weighed in all animals: liver, kidney, spleen, heart, brain, pituitary, thymus, thyroid, adrenal, and reproductive organs (testis, epididymis, prostate, seminal vesicle, ovary, and uterus). Histopathology results were reported for the following organs: lung, cecum, ileum, pancreas, liver, kidney, testis, epididymis, prostate, and pituitary gland (other organs may have been examined as well).

Both male and female rats at the high dose of 30 mg/kg-day consumed less food than controls on administration day 7 (−17 and −14% relative to controls, respectively, p ≤ 0.01) but not at other time points (14, 21, and 28 days). Male rats receiving 30 mg/kg-day exhibited lower body weights (−7%) on Days 7 and 14, but there were no statistically significant differences in body weight at Day 21 or 28 or after the recovery period, or in body-weight gains over the full treatment or recovery periods (terminal body weights changes are displayed in Table B-1).

Females exhibited no significant differences in body weight. Salivation was observed in small numbers of males and females (n = 1 or 2) at the high dose; no other clinical signs were noted. Reactivity, righting reflex, and forelimb and hindlimb grip strength were not significantly affected by exposure at any dose. At the end of exposure, statistically significant decreases in motor activity counts were observed at doses of 10 and 30 mg/kg-day in male rats (−63 and −53%, respectively; see Table B-1 for more details); no significant differences were observed for females. There were no differences in motor activity between control and high-dose rats after the recovery period. No treatment-related urinalysis changes were apparent. Male rats exhibited statistically significant longer PT (23–36% at ≥10 mg/kg-day) and APTT (41% at 30 mg/kg-day; see Table B-1) relative to controls at the end of treatment, while females did not; there were no other effects on hematology at the end of treatment and none after recovery. Statistically significant clinical chemistry findings in males at the end of exposure were increased calcium (+5%), increased alpha 2u-globulin (αu-g) and β globulin protein fraction percentages (+14%), and decreased albumin protein fraction percentages (−6%) and A/G ratios (−13%) in males receiving 30 mg/kg-day dibenzothiophene (see Table B-1). Females receiving the highest dose had significantly higher total cholesterol than controls (+54%) (see Table B-1). After the recovery period, the only observed changes were significant decreases in blood glucose in males and decreases in calcium and increases in chloride and α_1_ globulin protein fraction percent in females (data not shown). Although there were no significant changes in most serum hepatocellular/hepatobiliary markers (ALT, AST, ALP, GGT, and total bilirubin [data not shown]) in male and female rats, the decreases in albumin protein fraction and A/G ratio in males at 30 mg/kg-day are indicative of potential liver damage and are consistent with other liver effects observed in exposed rats (see below for more details).

Dose-related, statistically significant increases in relative liver weights occurred at ≥10 mg/kg-day in males (11–38%) and females (10–27%) (see Table B-1). Absolute liver weight was statistically significantly increased at the low dose in females (18%) and at the high dose in males and females (29–31%); however, the changes did not follow a dose-response gradient. Female rats displayed biologically significant (≥10%) increases in absolute liver weight at all doses, while male rats achieved biologically significant increases in absolute liver weight at only the low and high doses. Males, but not females, exhibited dose-related, significant increases in relative kidney weights at ≥10 mg/kg-day (+9% at 10 mg/kg-day and +12% at 30 mg/kg-day). Absolute kidney weights increased significantly in females at 3 mg/kg-day (+14%) but there was no dose-response correspondence. Gross necropsy findings at the end of the exposure period consisted of dark brown discoloration of the liver in six of six female rats at 30 mg/kg-day (no other female groups and no males exhibited this change). Histopathology findings in the liver (see Table B-2) consisted primarily of centrilobular hepatocyte hypertrophy (six of six high-dose animals of both sexes and one of six females at 10 mg/kg-day; graded as slight in all cases). One high-dose male rat had a finding of slight focal liver necrosis. These lesions were not observed in the control group. Males (six of six in the high-dose group, two of six in the mid-dose group, and one of six in the low-dose group) also exhibited hyaline droplets and eosinophilic bodies (all graded as slight) in the proximal tubular epithelium of the kidney (see Table B-2). The kidney changes, but not the liver changes, persisted until the end of the recovery period in some rats.

No-observed-adverse-effect level (NOAEL) and lowest-observed-adverse-effect level (LOAEL) values of 3 and 10 mg/kg-day, respectively, are identified from this study based on ≥10% increases in relative liver weights in both sexes considered biologically significant, as well as statistically significant reductions in motor activity and increased PT in males. There is some uncertainty due to lack of a full English language report. Although ≥10% increases in absolute liver weights were observed at a dose of 3 mg/kg-day in rats, the changes in absolute liver weights did not follow a dose-response gradient. Further, the increase in relative liver weight in the mid- and high-dose groups is supported by increased incidence of hepatocyte lesions in male and female rats at ≥10 mg/kg-day (mostly hypertrophy but also possible evidence of necrosis) and significant decreases in albumin protein fraction and A/G ratio in males at 30 mg/kg-day. Biologically significant increases (≥10%) in relative kidney weights were observed in males at 30 mg/kg-day and these animals also showed evidence of kidney lesions (100% incidence of hyaline droplets and eosinophilic bodies). The administered doses of 0, 3, 10, and 30 mg/kg-day correspond to human equivalent doses (HEDs) of 0, 0.75, 2.5, and 7.4 mg/kg-day for males, and 0, 0.68, 2.2, and 6.7 mg/kg-day for females, respectively.^2^

#### Subchronic/Chronic Studies

##### Thomas et al. (1942)

In a published, peer-reviewed study, Thomas et al. (1942) administered dibenzothiophene (purity not reported) in the diet of male albino rats (source and number not reported) aged 25–28 days with an average body weight of 48 g at the beginning of the study. The animals received 0.25, 0.50, or 1.00% dibenzothiophene in the diet for the first 4 days of the dosing period (number of animals per dose group not reported). Because of low food intakes and decreases in body weight, the doses were decreased to 0.025, 0.050, or 0.100% dibenzothiophene for the remainder of the 165-day dosing period. Adjusted daily doses (ADDs) are estimated to be 13, 27, and 63 mg/kg-day, respectively, based on total dibenzothiophene consumption reported by the study authors and time-weighted average (TWA) body weights obtained by digitizing the growth curves provided by the study authors. Animals were housed five to a cage; other details regarding animal husbandry were not provided. Appearance and behavior were recorded by the study authors “throughout the duration of the study.” Food and water were provided ad libitum; animals and food cups were weighed twice a week for the duration of the study. Experimental data for each exposure group were compared with data for age- or body-weight-matched historical control animals; the type of historical control used for each endpoint is listed below with the results for that endpoint.

At study termination, animals were sacrificed, and histopathological examinations were performed. The study authors noted that they used a necropsy technique previously described by Wilson et al. (1938); the spleen, liver, adrenal glands, kidneys, testes, ovaries, and heart were weighed under this necropsy protocol. Histopathological sections of the liver, spleen, adrenal gland, heart, bladder, intestine, lung, testis, and stomach were prepared from five animals in each exposure group and stained with hematoxylin and eosin (Thomas et al., 1942). Frozen sections of the livers from three animals in the high-dose group and all animals in the low-dose group were stained with Sudan IV. Blood was collected on Days 107 and 157 from the tails of five high-dose animals and analyzed for hemoglobin and for erythrocyte, reticulocyte, and total and differential WBC counts. Although the study authors indicated statistical significance of their findings, no information was provided regarding their statistical methods. This study was performed prior to the adoption of Good Laboratory Practice (GLP), and little information regarding the laboratory procedures was provided. The study authors also reported a second experiment examining the presence of dibenzothiophene metabolites in the urine of rabbits (see Table 4B in Section 2.3.2).

No deaths or clinical signs of toxicity were reported during the study. Body weights throughout the course of the study were presented graphically, and mean terminal body weights were provided in numerical form for each exposure group (see Table B-3). A dose-dependent decrease in body weight was observed; however, the study authors attributed this to reduced food consumption and did not consider it a direct effect of dibenzothiophene. For the evaluation of organ weights, animals dosed with dibenzothiophene were compared with laboratory historical controls matched according to body weight. As a result, the differences from the control group approximate a change in relative (to body weight) organ weight. The only significant effects on organ weight observed were in the liver and spleen. Although statistical significance for weight changes in both the liver and spleen were noted by the study authors, neither an indication of the dose at which significance occurred nor any levels of significance were reported. Data for these organs are presented in Table B-3. Liver weights increased (7–115%) in a dose-dependent manner, with changes >10% occurring at ≥27 mg/kg-day. Spleen weights decreased (29–57%) in a dose-dependent manner. The decreased spleen weight may be related to the decreased food consumption, as spleen weight has been shown to decrease disproportionately to body weight when food consumption is decreased (Peters and Boyd, 1966). Gross examination revealed that the livers in the mid- and high-dose animals were large and presented a yellowish, fatty appearance. Spleens appeared normal except for a reduction in their sizes upon gross examination. Liver and kidney histopathological lesions were reported by the study authors; however, incidence was not reported, and no control group was examined. Histopathology of livers from the high-dose animals revealed extensive fatty metamorphosis of the hepatic cells, abnormal fat accumulation, and irregular vacuolation of the parenchymal cells extending throughout the lobules. Livers from high-dose animals also had some cells with indistinct borders where it appeared that adjacent cells had fused. Other liver cells had a rim of homogenous, deeply stained cytoplasm surrounding groups of vacuoles. Similar changes, but less severe, were observed in the mid-dose group. The liver effects observed in the low-dose group were described as “still less severe” than those observed at the mid-dose. There was no evidence of fibrosis or necrosis, and the Kupffer cells were unchanged. Kidneys of all exposed animals had slight-to-moderate, light brown, granular pigmentation in the epithelial cells of the proximal convoluted tubules, but there was no evidence of cell destruction. Histopathological abnormalities in other organs, including the spleen, were not observed. Hematological effects were compared to age-matched controls. There were no hematological effects observed based on the blood analyses of the high-dose animals when compared with age-matched laboratory historical controls. In addition, the study authors noted that similar blood counts were seen in previously published hematological data from untreated animals and in animals treated with the closely related compound, diphenylene oxide.

The outstanding limitations in the study design and data reporting, primarily the lack of a concurrent control group or reporting on the number of test animals, prevent further interpretation of the results or the determination of NOAEL and LOAEL values. The administered doses of 0, 13, 27, and 63 mg/kg-day correspond to HEDs of 0, 2.9, 5.9, and 13 mg/kg-day, respectively.^3^

#### Reproductive/Developmental Studies

No studies were identified.

### 2.2.2 Inhalation Exposures

No studies were identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

### 2.3.1 Genotoxicity

The available genotoxicity data for dibenzothiophene are limited and primarily indicate a lack of genotoxic activity. Dibenzothiophene was negative for mutagenicity in the Ames test involving Salmonella typhimurium strains at doses up to 5,000 μg/plate (JECDB, 2010a; Madill et al., 1999; Mcfall et al., 1984; Pelroy et al., 1983; Dickson and Adams, 1980), with or without metabolic activation. A positive result was reported for mutation in the photoluminescent bacterium, Vibrio fisheri, in the Mutatox test (without activation), although the study authors noted that a positive response in this assay can occur without deoxyribonucleic acid (DNA) damage (Madill et al., 1999). Studies in mammalian cells were negative for mutation in Chinese hamster ovary (CHO) cells at doses up to 100 μg/mL (Rasmussen et al., 1991) and chromosomal aberrations (CAs) in Chinese hamster lung fibroblast (CHL) cells at doses up to 116 μg/mL for 24 hours with S9 or up to 1,850 μg/L for 6 hours without activation (JECDB, 2010b). A study in cultured rainbow trout liver RTL-W1 cells reported induction of micronucleus formation by dibenzothiophene, with an EC_25_ (the concentration causing 25% of the maximum effect level of the standard, 4-nitroquinoline oxide) of 10.8 mg/mL (3.2 mg/L after correction for estimated losses due to volatilization, sorption, etc.) (Brinkmann et al., 2014). This is of uncertain relevance to mammals, however, Amat et al. (2004) observed weak DNA adduct formation at cytotoxic concentrations in HepG2 human hepatocellular carcinoma cells exposed to ≥50 μM dibenzothiophene. These studies are further described in Table 4A.

Table 4A Summary of Dibenzothiophene (CASRN 132-65-0) Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested^a^ | Results Without Activation^b^ | Results With Activation^b^ | Comments | Reference
Genotoxicity studies in prokaryotic organisms
Reverse mutation | Ames assay using Salmonella typhimurium strain TA98 treated with 10–100 μg dibenzothiophene per plate dissolved in DMSO and incubated at 37°C for 48 h with Aroclor 1254-induced rat-liver S9 homogenate activation (S9 concentrations of 4, 10, or 20%) | 100 μg/plate | ND | − | Not mutagenic at any dose; S9 volume did not affect activity. | Mcfall et al. (1984)
Reverse mutation | Ames assay using S. typhimurium strains TA98, TA100, TA1535, TA1537, and TA1538 treated with an unreported quantity of dibenzothiophene dissolved in DMSO with Aroclor 1254-induced rat-liver S9 homogenate activation | NR | ND | − | Not mutagenic; mutagenicity results presented as revertant ratio (number of revertants per plate/number of spontaneous revertants); dibenzothiophene reportedly had “no mutagenic response” with an average revertant ratio <2.0. | Dickson and Adams (1980)
Reverse mutation | Ames assay using S. typhimurium strains TA98, TA100, TA1535, and TA1537 treated with 2–500 μg dibenzothiophene per plate dissolved in DMSO with and without Aroclor 1254-induced rat-liver S9 homogenate activation | 500 μg/plate | − | − | Not mutagenic at any dose. | Pelroy et al. (1983)
| Ames assay (preincubation modified plate incorporation test) using S. typhimurium strains TA98 and TA100 treated with unspecified three-log dose dilutions of dibenzothiophene in DMSO with or without S9 activation; control experiments conducted with DMSO as negative control and BaP and 4-nitroquinoline-N-oxide as positive controls | NR | − | − | Not mutagenic at any dose. | Madill et al. (1999)
| Ames assay using S. typhimurium strains TA98, TA100, TA1535, and TA1537 and Escherichia coli WP2uvrA treated with dibenzothiophene in DMSO at 78.1– 5,000 μg/plate with or without S9 activation; negative and positive controls included | 5,000 μg/plate | − | − | Not mutagenic at any dose. Precipitation and growth inhibition were seen in all strains at the higher dose levels tested (1,250–5,000 μg/plate). | JECDB (2010a)
Mutation | Mutatox assay in which photoluminescent bacterium Vibrio fisheri were incubated with 0.01– 5 μg/tube dibenzothiophene in methanol for 45 min with or without S9 activation; control experiments conducted with methanol as negative control and BaP and phenol as positive controls | 0.38 μg/tube | + | − | In absence of activation, positive response (twofold increase in light output vs. negative control) in 5 of 10 tubes in dilution series, with 0.38 μg/tube dibenzothiophene being the lowest effective dose. In presence of activation, negative at all doses up to 5 μg/tube. Positive response in this assay can occur without DNA damage (e.g., phenol, the positive control, is nongenotoxic and noncarcinogenic). | Madill et al. (1999)
Genotoxicity studies in nonmammalian eukaryotic cells—in vitro
Micronucleus formation | Micronucleus assay conducted in rainbow trout liver RTL-W1 cells using 0.3–41 mg/L dibenzothiophene | 10.8 mg/L (EC_25_) | + | ND | EC_25_ = 10.8 mg/L for micronucleus induction (3.2 mg/L after correction for estimated losses due to volatilization, sorption, etc.). | Brinkmann et al. (2014)
Genotoxicity studies in mammalian cells—in vitro
Mutation | Chinese hamster ovary (CHO-K1BH4) cells treated with 1– 100 μg/mL dibenzothiophene with Ham’s F12 medium, activated with 4% Aroclor-induced rat-liver S9 solution and incubated for 5 h; control experiments conducted with DMSO as the control and methyl methane sulfonate as a positive control | 100 μg/mL | ND | − | Not mutagenic at any dose. | Rasmussen et al. (1991)
CAs | Cultured Chinese hamster lung fibroblast CHL/IU cells incubated with dibenzothiophene at 7.23–116 μg/mL for 6–24 h (without S9) or 57.8–1,850 μg/mL for 6 h (with S9) | 1,850 μg/mL | − | − | No effect on structural or numerical aberrations at any dose. Toxicity was observed at the higher doses in the tests without S9 (86.9–116 μg/mL) but not in the tests with S9. | JECDB (2010b)
DNA adduct formation | Cultured HepG2 human hepatocellular carcinoma cells incubated with 0.25–150 μM dibenzothiophene (dissolved in methanol) for 24 or 48 h; control experiments conducted with culture medium alone as negative control and BaP in DMSO as positive control. | 50 μM | ± | ND | Weak DNA adduct formation at cytotoxic concentrations. | Amat et al. (2004)

a Lowest effective dose for positive results, highest dose tested for negative results.

b + = positive; ± = weakly positive; − = negative.

BaP = benzo[a]pyrene; CA = chromosomal aberration; DMSO = dimethylsulfoxide; DNA = deoxyribonucleic acid; EC_25_ = the concentration causing 25% of the maximum effect level of the standard, 4-nitroquinoline oxide; ND = no data.

### 2.3.2 Metabolism/Toxicokinetic and Supporting Animal Studies

Additional studies investigating the metabolism of dibenzothiophene in rats (Jacob et al., 1991; Vignier et al., 1985), elimination of dibenzothiophene in the urine of rabbits (Thomas et al., 1942), acute toxicity of dibenzothiophene in mice (Leighton, 1989), and toxicity of dibenzothiophene by weekly injection in rats (Silva et al., 2015), as well as in vitro studies of effects of dibenzothiophene on aggregation of platelets (Chaudhury et al., 1988) and viability of differentiated SK-N-SH human neuroblastoma cells (Sarma et al., 2017) are also available. See Table 4B for details of these studies.

Table 4B Other Studies

Test | Materials and Methods | Results | Conclusions | Reference
Supporting Animal Studies
Short-term | CD-1 mice treated via gavage.; [underlined: Pilot range-finding studies:] 4 mice/sex/dose, single dose of 0–3,250 mg/kg or four consecutive daily doses of 0–325 mg/kg; necropsy performed 24 h after last dose; blood taken from hearts of mice and examined for hematological effects; liver, kidney, spleen, heart, lungs, thymus, and duodenum examined at necropsy.; [underlined: LD_50_ Experiment 1:] 12 male mice/dose, 12 vehicle controls, 8 untreated controls; single doses of 0, 260, 374, 540, 777, 1,118, or 1,609 mg/kg; LD_50_ determined at 7 d; surviving mice sacrificed on day 14 for histology of liver, lung, heart, and thymus.; [underlined: LD_50_ Experiment 2:] 12 mice/treatment group, 5 preinduced vehicle controls; MFO pretreatment (one i.p. injection of 3-methylcholanthrene [80 mg/kg] followed by daily i.p. injections of phenobarbital [50 mg/kg] in sterile saline for 3 d) followed 24 h later by single doses of 0, 215, 265, 325, 400, 492, 605, or 744 mg/kg. | [underlined: Pilot range finding studies:] No treatment-related hematological changes seen; no treatment-related histological lesions seen in the kidney, duodenum, spleen, or heart; liver lesions included centrilobular or periacinar degeneration and necrosis.; [underlined: LD_50_ experiments:] All mortality occurred within 72 h of treatment and was increased in groups with prior induction of MFO; animals were sluggish; gross lesions in mice found dead included pulmonary congestion and edema, mild to moderate hydrothorax, intestinal hemorrhage, and mottled livers; all MFO-induced mice had mild fibrinous peritonitis; histological lesions included severe centrilobular hepatic necrosis across doses in both experiments, necrosis of lymphocytes in thymic cortices at ≥540 mg/kg in Experiment 1 and ≥265 mg/kg in Experiment 2, and degenerative changes in the walls of small arteries in the lung in five mice dosed with 265–492 mg/kg (Experiment 2). | Without induction: acute LD_50_ of 470 mg/kg; with prior induction of MFO, acute LD_50_ of 335 mg/kg; preinduction of MFO potentiated the toxicity of dibenzothiophene. | Leighton (1989)
Injection | Male Wistar rats were given weekly i.p. injections of saline (n = 5), soy oil (n = 5) or 30 mg/kg dibenzothiophene in soy oil (n = 15) for 10 wk and were examined after a latency period of 14 wk for hematology (RBC, hematocrit, WBC total and differential), serum chemistry (amylase, ALT, AST), organ weights (liver and spleen), histology (liver, spleen, lungs, and intestines), immunohistochemistry (using anti-CEA and anti-CD44 antibodies) and proteomic analysis. Body weights were recorded weekly. | There were no treatment-related effects on body weight, hematology, serum chemistry, or organ weights. Histopathological examination showed effects only in the intestines, including increased incidence of cellular atypia in the mucosa and submucosa, mucosa inflammation, necrosis, and hyperplasia of lymphoid nodules in both the large and small intestines. Counts of cells positive for antibody labelling were increased threefold (either CEA or CD44), suggesting the presence of preneoplasia. Proteomic analysis identified 23 proteins showing altered levels (≥1.5-fold change versus controls) in the small intestine, with functions including heat-shock response; cytoskeleton organization; antioxidant activity; cell signaling; carbohydrate, lipid and nucleotide metabolism; and protein folding. | Dibenzothiophene produced dysplastic lesions in the large and small intestines of male rats treated weekly by injection of 30 mg/kg in soy oil for 10 wk and examined at 24 wk. | Silva et al. (2015)
Metabolism/toxicokinetic
Metabolism/ Toxicokinetic | Male Wistar rat (number not specified), treated with daily i.p. injections of 40 mg/kg dibenzothiophene for 3 d, 3-methylcholanthrene for 3 d, 500 mg/kg Aroclor 1254 for 5 d, or twice daily i.p. injections of 40 mg/kg phenobarbital for 4 d, then starved for 24 h after final injection; liver microsomes isolated; in vitro oxidation assay performed using dibenzothiophene (0.02–0.50 mM) and rat liver microsomal suspension (10 μL). | Dibenzothiophene metabolic pathway determined to be S-oxidation with metabolites of dibenzothiophene-5-oxide (primary) and dibenzothiophene-5-dioxide (secondary); Aroclor 1254, 3-methylcholanthrene, and phenobarbital increased rate of formation of sulfoxide, but dibenzothiophene pretreatment had no effect; carbon monoxide inhibited sulfoxidation. | Dibenzothiophene metabolite, dibenzothiophene-5-oxide, was further oxidized to dibenzothiophene-5-dioxide; CYP450 monooxygenases most likely involved in the metabolism. | Vignier et al. (1985)
| Male Wistar rat (number not specified), treated with i.p. injections of 40 mg 5,6-benzoflavone/kg for 3 d, 200 mg Aroclor/kg once, or 80 mg phenobarbital/kg in 0.9% NaCl over 3 d and sacrificed 24 h after last dose; microsomes from four animals per group were incubated with 50 μmol/L dibenzothiophene for 20 min at 37°C and analyzed; solvent-only controls. | Metabolic products were sulfoxide (main product) and sulfone; no pretreatments affected sulfoxide formation, but pretreatments with phenobarbital and Aroclor increased sulfone formation. | Dibenzothiophene metabolites (using rat microsomes) were sulfoxide and sulfone, controlled by different enzymes; only the one responsible for sulfone formation can be induced by CYP450 inducers such as phenobarbital. | Jacob et al. (1991)
| One rabbit (sex and strain not specified) given an emulsion of 2 g dibenzothiophene in water administered via stomach tube; urine collected (time not specified) and analyzed. | Main excretion product was mono-hydroxy- diphenylene sulfone. | Dibenzothiophene oxidized to mono-hydroxy-diphenylene sulfone in the rabbit. | Thomas et al. (1942)
Mode of action/mechanistic
In vitro | Aggregation of platelets from blood collected from male Sprague Dawley rats was measured photometrically after incubation for 2 min with 1, 3, or 5 μL of dibenzothiophene in DMSO or DMSO alone. Tests were also conducted with addition of thrombin or ADP to stimulate platelet aggregation, mobilization of internal calcium stores within platelets, and uptake of extracellular calcium by platelets. | Platelet aggregation was significantly reduced in a dose-related manner by dibenzothiophene relative to controls. Dibenzothiophene also reduced aggregation stimulated by thrombin or ADP and reduced extracellular calcium uptake by platelets. | Dibenzothiophene may inhibit platelet aggregation by bringing about alterations in the platelet plasma membrane. | Chaudhury et al. (1988)
In vitro | Differentiated SK-N-SH human neuroblastoma cells were cultured for 24 h with 5–100 μM dibenzothiophene and assessed for viability and production of ROS relative to unexposed controls. | Neuroblastoma cell viability was reduced relative to controls at all test concentration, with LC_10_ = 5.07 μM and LC_20_ = 47.26 μM. Significant increases in ROS were seen at ≥10 μM. | Dibenzothiophene induces neuronal cell damage by a mechanism that involves generation of oxidative stress. | Sarma et al. (2017)

ADP = adenosine diphosphate; ALT = alanine aminotransferase; AST = aspartate aminotransferase; CYP450 = cytochrome P450; DMSO = dimethyl sulfoxide; i.p. = intraperitoneal; MFO = mixed function oxidase; NaCl = sodium chloride; RBC = red blood cell; ROS = reactive oxygen species; WBC = white blood cell.

2 Administered doses were converted to HEDs by multiplying by dosimetric adjustment factors (DAFs) of 0.250, 0.248, and 0.247 for low-, mid-, and high-dose males and 0.226, 0.223, and 0.222 for low-, mid-, and high-dose females calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Study-specific TWA animal body weights of 0.272, 0.264, and 0.259 kg for low-, mid-, and high-dose males, and 0.182, 0.174, and 0.171 kg for low-, mid-, and high-dose females were used. For humans, the reference value of 70 kg was used for body weight, as recommended by U.S. EPA (1988).

3 Administered doses were converted to HEDs by multiplying by DAFs of 0.225, 0.219, and 0.208 for low-, mid-, and high-dose rats calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Study-specific estimated average animal body weights of 0.179, 0.161, and 0.130 kg for low-, mid-, and high-dose rats were used. For humans, the reference value of 70 kg was used for body weight, as recommended by U.S. EPA (1988).